# Stakeholder Panel

The following individuals served as members of the Stakeholder Panel described in this report. Broad expertise and perspectives are sought and their contributions were invaluable. Divergent and conflicted opinions are common and perceived as healthy scientific discourse. Therefore, in the end, study questions, design, and/or methodologic approaches do not necessarily represent the views of individual technical and content experts.

- Todd Alonzo, Ph.D.
  University of Southern California
  Arcadia, CA
- Robert Carey, B.S.
  Georgia Prostate Cancer Coalition/Georgia Ovarian Cancer Alliance
  Atlanta, GA
- W. David Dotson, Ph.D.
  Centers for Disease Control and Prevention
  Atlanta, GA
- John L. Gore, M.D., M.S.
  University of Washington
  Seattle, WA
- Roger Klein, M.D., J.D.
  Blood Center of Wisconsin
  Milwaukee, WI
- Howard Parnes, M.D.
  Division of Cancer Prevention
  National Cancer Institute
  Bethesda, MD
- Richard Rainey, M.D.
  Regence BlueShield of Idaho
  Lewiston, ID
- Andrew Stephenson, M.D.
  Center for Urologic Oncology
  Cleveland Clinic
  Cleveland, OH