# Acknowledgments

The Research Team would like to acknowledge the following individuals for their contributions to this report: Hussein Noorani, M.S.; Glenn Palomaki, Ph.D.; Linda A. Bradley, Ph.D., FACMG; Elaine Alligood, M.L.S.; Lisa Sarsany, M.A.; Lisa Garofalo, B.A.; and Kathleen M. Ziegler, Pharm.D.