# Discussion

Using the 2012 draft CER on PCA3 Testing in the Diagnosis and Management of Prostate Cancer, and with input from a diverse group of Stakeholders, a 10-step process was followed for identifying and prioritizing clinically important research needs and research questions. The research needs reflecting the breadth of the original CER Key Questions, included uncertainty about the diagnostic performance of PCA3, its ability to produce better biopsy or treatment decisions, and its impact on long-term health outcomes. The final research questions added specificity to these research needs. Through the process employed, a final list of three research needs and six associated research questions was compiled.

Given the complexity of topics discussed in the CER, the decision to limit the future research needs project to items within the clinical scope of testing, and to not address more general methodological and statistical issues, assured focus to the project. Although the CER did identify methodological problems that are worth addressing (including a general poor quality of the studies themselves), these are not unique to PCA3 and warrant further discussion in future projects, perhaps in the form of a series of methods papers.

There are several strengths to the process used to identify and prioritize research needs and research questions. First, the Stakeholders came from a wide variety of relevant disciplines, which was important to provide a balanced and broad perspective on the research needs being discussed. Second, the use of a variety of interactive communication approaches, including a one-on-one orientation to the project, two teleconferences, and the use of e-mails and internet surveys, allowed work to proceed in an efficient and timely manner. Third, there was active and vigorous participation by the Stakeholders in all phases of the project.

The Stakeholders agreed with the findings of the CER and recognized that work needed to be done to better understand the clinical performance, impact on decisionmaking, and health outcomes of PCA3 testing. Three stakeholders had previously served as Key Informants or members of the Technical Expert Panel for the PCA3 CER, and two had provided peer review of PCA3 CER document. The patient advocate was particularly helpful in calling attention to the patient’s perspective on how important it would be to determine if PCA3 is viewed as a benefit, or as simply another confounding factor in the complex and difficult process of decisionmaking in at-risk patients.

In evaluating the prioritization of the research needs by the Stakeholders, a logical pattern evolved that seemed to fit well with the development and credentialing of a new diagnostic test. Highest priority went to establishing the diagnostic accuracy of the test. This is a highly pragmatic starting point, since without a clinically validated signal, risk of failure in further exploration of the use of a new test is high. Of second priority was defining what information the test signal conveyed about aggressiveness of missed or identified disease and how this information might be used in decisionmaking. It is likely that a test with a weak signal or that was poor at discriminating between indolent and aggressive disease might not convince physicians or patients, in either real or simulated studies, to make changes in management choices. The value of such a test would obviously be limited. Finally, in order to understand how a test impacts health outcomes, there is a need for either clinical studies or for a strong chain of evidence based on carefully selected and documented surrogates for predicting outcomes.

Because of the well-established hierarchal approach provided by the Stakeholders, the final rating of research questions was modified to rate questions within each research need rather than to generically evaluate these questions collectively across the research needs.

Recognizing the difficulty in performing the randomized clinical trial that would be required to establish the ultimate benefits and risks of testing, the Stakeholders provided the pragmatic direction of considering mechanisms for establishing how well PCA3 served as a prognostic marker of tumor aggressiveness. This association, if established strongly enough, was noted to be a potential measurement that could, by itself, convey value to testing by improving both diagnostic and treatment choices. Suggestions from the Stakeholders included use of prognostic features on biopsy, changes in grading between biopsy and prostatectomy, and add-on studies to ongoing investigations of active surveillance in carefully chosen patients.

## Conclusions

This PCA3 FRN project was built from the PCA3 CER. A panel of Stakeholders refined and prioritized research needs and research questions. The results of this process are the following three top-ranked research needs and six research questions.

Research Need Number 1: Lack of information on the comparative performance of PCA3 and currently used biomarkers to detect prostate cancer; lack of “matched studies” on comparators.

- Research Question 1.1: What is the comparative effectiveness of PCA3 compared to the two commonly used add on tests of fPSA and tPSA velocity/doubling time in predicting prostate biopsy results?
- Research Question 1.2: What are PCA3’s diagnostic performance characteristics in patients with elevated tPSA levels?
- Research Question 1.3: What is the comparative effectiveness of PCA3 compared to externally validated nomograms in predicting prostate biopsy results?

Research Need Number 2: Lack of studies on how PCA3 actually helps in biopsy or treatment decision making.

- Research Question 2.1: What information does PCA3 provide about the aggressiveness of prostate cancer? Do positive results correlate to tumors with aggressive features on biopsy or upgrading of tumors on prostatectomy? Do negative results correlate to tumors that may not require identification or aggressive treatment?
- Research Question 2.2: Does the addition of PCA3, either alone, or in combination with other markers, change prostate cancer biopsy or treatment decisionmaking for the patient or physician?

Research Need Number 3: Uncertainty of impact of PCA3 in biopsy decisionmaking on long term health outcomes.

- Research Question 3.1: Does addition of PCA3 testing change long term health outcomes in prostate screening?