# Background

## Clinical Context

Cancer of the prostate is the second most common cancer and the second leading cause of cancer deaths in men in the United States.1 Most patients have indolent tumors, and may live for years with no or minimal effects, ultimately dying of other causes.2 The lifetime risk of being diagnosed with prostate cancer is 16 percent, but the lifetime risk of dying from the disease is only three percent.3 However, some patients have aggressive tumors that spread beyond the prostate, resulting in significant morbidity and death.

The rationale for prostate cancer screening using serum total prostate specific antigen (tPSA) levels4,5 was that early detection of prostate tumors would lead to timely intervention and reduced prevalence of disease. However, screening programs have generated considerable controversy, with concerns expressed that they lead to over-diagnosis and over-treatment of prostate cancer and associated harms.2 The United States Preventive Services Task Force has recently issued a recommendation against PSA-based screening for prostate cancer;6 however, the balance of benefits and harms of tPSA screening remains controversial.7

In 1999, researchers reported that the prostate cancer antigen 3 gene (PCA3; also known as DD3), was highly overexpressed in prostate cancer relative to normal prostate or benign prostatic hyperplasia tissue.8 Subsequently, noninvasive PCA3 tests on messenger RNA from urine were developed. Two proposed intended uses of PCA3 and comparator tests were to inform decisionmaking about biopsy or rebiopsy of men with elevated tPSA and/or other risk factors. A third purpose was to inform decisions about treatment (e.g., active surveillance, prostatectomy, radiotherapy) by classifying disease in men with positive biopsies as low risk (indolent) or high risk (aggressive). The U.S. Food and Drug Administration recently approved a PCA3 assay for use in men with one or more previous negative biopsies to inform decisionmaking about repeat biopsy.

In April 2012, a draft comparative effectiveness review (CER) on PCA3 Testing in the Diagnosis and Management of Prostate Cancer was completed. The review had two aims. The first was to evaluate the comparative effectiveness of replacing or supplementing existing testing approaches for decisionmaking on when to biopsy (KQ 1) or rebiopsy (KQ 2) men at risk for prostate cancer. Key Questions 1 and 2 were as follows:

- KQ 1: In patients with elevated tPSA and/or an abnormal DRE who are candidates for initial prostate biopsy, what is the comparative effectiveness of PCA3 testing as a replacement for, or supplement to, standard tests, including diagnostic accuracy (clinical validity) for prostate cancer, intermediate outcomes (e.g., improved decisionmaking about biopsy), and long-term health outcomes (clinical utility), including mortality/morbidity, quality of life, and potential harms?
- KQ 2: In patients with elevated PSA and/or an abnormal DRE who are candidates for repeat prostate biopsy (when all previous biopsies were negative), what is the comparative effectiveness of PCA3 testing as a replacement for, or supplement to, standard tests, including diagnostic accuracy (clinical validity) for prostate cancer, intermediate outcomes (e.g., improved decisionmaking about biopsy), and long-term health outcomes (clinical utility), including mortality/morbidity, quality of life, and potential harms?

The second aim of the review was to evaluate the comparative effectiveness of replacing or supplementing existing approaches for categorizing prostate cancer biopsy-positive men as having high- or low-risk cancer, and making decisions about treatment (e.g., active surveillance or aggressive therapy; KQ 3). Key Question 3 was as follows:

- KQ 3: In patients with a positive biopsy for prostate cancer who are being evaluated to distinguish between indolent and aggressive disease, what is the effectiveness of using PCA3 testing alone, or in combination with the standard prognostic workup (e.g., tumor volume, Gleason score, clinical staging) or monitoring tests (e.g., PSA, PSA velocity), with regard to diagnostic accuracy (clinical validity) for aggressive (high risk) prostate cancer, intermediate outcomes (e.g., improved decisionmaking about prognosis and triage for active surveillance and/or aggressive treatment) and long-term health outcomes (clinical utility), including mortality/morbidity, quality of life, and potential harms?

## Summary of PCA3 CER Results and Strength of Evidence

Our analyses revealed that PCA3 had improved diagnostic accuracy compared to tPSA in identifying the presence or absence of prostate cancer, with no differences resulting from biopsy status (initial versus repeat biopsy); however, the strength of evidence for this finding was low. The draft PCA3 CER data from matched studies was insufficient to answer all other questions posed. In addition, issues were raised about methodological flaws in current research approaches, including risk of biases related to selection of study subjects, the generally poor quality of individual studies, and the lack of longitudinal studies to investigate the impact of early decisionmaking on long-term health outcomes. Evidence gaps were identified and preliminary research questions to address those gaps were posed. Conclusions by Key Question and strength of evidence are detailed in Appendix A.

## PCA3 CER Evidence Gaps

There were several important evidence gaps identified in the draft PCA3 CER:

- How much improvement in diagnostic accuracy is needed for any new test to impact biopsy decisionmaking.
- The potential of adding PCA3 alone or with other biomarkers to change decisionmaking in practice.
- How PCA3 compares in terms of diagnostic accuracy and clinical utility to the two more frequently used add on tests (free PSA, PSA velocity) that have appeared in guidance documents.
- The need for matched studies (studies which in which results of testing between PCA3 and the comparators of interest are performed and reported in the same individuals rather than only in groups of individuals) not derived from “convenience” populations (e.g., biopsy referral centers), and more data on how key demographic factors (family history, race) impact on the performance of PCA3 and comparators.
- The need for outcome studies to determine how well PCA3 and other comparators used to categorize risk as insignificant/indolent or aggressive to predict the behavior of tumors over time.
- A range of methodological and statistical questions relating to modeling, assessing impact of verification bias, identifying most effective cutoffs for tests based on ROC analysis, and designs for future studies.

The analytical frameworks that guided the draft PCA3 CER are provided in Figure 1 and Figure 2.

Figure 1 Future research needs for PCA3 testing: analytic framework for PCA3 as a diagnostic indicator for biopsy or re-biopsy in patients with elevated tPSA and/or abnormal digital rectal examination (KQ 1 and 2)

Abbreviations: PCA3 = prostate cancer antigen 3 gene; PSA = prostate-specific antigen; tPSA = total prostate-specific antigen

^a^ Patients may be evaluated for initial biopsy or rebiopsy after one or more negatives.

Note: For link B, PCA3 shows increased diagnostic accuracy compared to tPSA (low strength of evidence); for all other links (comparators and outcomes) strength of evidence is insufficient.

Figure 1 depicts the framework for KQ1 with the patient population of male patients with an elevated PSA level and/or abnormal digital rectal exam (DRE). This figure depicts the comparative effectiveness of using PCA3 testing versus other tests (e.g., PSA) for intermediate outcomes and long-term health outcomes. Direct evidence of testing impact on health outcomes (e.g. reduced mortality/morbidity, quality of life) is shown by Link A. In the indirect chain of evidence, Link B addresses the diagnostic accuracy (clinical validity) of the PCA3 test and designated comparators. Link C addresses the impact of test results on the decision to proceed to the initial prostate biopsy, which, in turn, impacts the intermediate outcomes (Link D) and may affect health outcomes (Link E). Intermediate outcomes may have an association with long term health outcomes (Link F). Link G on the on the left focuses on adverse events/personal harms related to biopsy left addresses potential personal and clinical harms related to the effect of testing on the decision about biopsy, and on the right focuses on adverse events/personal harms related to biopsy. The framework for KQ2 is essentially the same, except the population is male patients with elevated PSA and/or DRE, as well as one or more previous negative prostate biopsies. Link C in this case addresses the impact of test results on the decision to proceed to repeat prostate biopsy.

Figure 2 Future research needs for PCA3 testing: analytic framework for PCA3 used to distinguish indolent versus aggressive prostate cancer (KQ3)

Abbreviation: PCA3 = prostate cancer antigen 3 gene

^a^ Diagnostic accuracy

Note: Strength of evidence insufficient for all links (comparators and outcomes).

Figure 2 depicts the comparative effectiveness of using PCA3 testing (alone or in combination with other biomarkers) and other commonly used tests (e.g., Gleason score and other pathological markers, percent positive cores) on intermediate and long-term health outcomes of interest. Direct evidence of the impact of testing on health outcomes (e.g., mortality, morbidity, function, quality of life) is shown by Link A. In the indirect chain of evidence, Link B addresses the diagnostic accuracy (clinical validity) of the tests in categorizing tumors as aggressive and insignificant/indolent Link C addresses the impact of test results on decisionmaking related to prognosis and triage for active surveillance versus aggressive treatment. This link, in turn, impacts other intermediate outcomes (Link D) and indirectly affects health outcomes (Link E). Intermediate outcomes may have an association with health outcomes (Link F). Link G on the left addresses potential harms related to the effect testing has on treatment decisions; Link G on the right focuses on clinical (e.g., incontinence, impotence, bowel dysfunction) and psychosocial (e.g., anxiety, self-image, quality of life) harms related to the treatment.