# Results From PCA3 Research Questions Prioritization Survey

Table H.1 Results from PCA3 research needs prioritization survey

Rank | Research Need | Research Questions | Total Votes | Total Score
1 | 1. Lack of information on the comparative performance of PCA3 and currently used biomarkers to detect prostate cancer; lack of “matched studies” on comparators | What is the comparative effectiveness of PCA3 compared to the two commonly used add-on tests of fPSA and tPSA velocity/doubling time in predicting prostate biopsy results? | 8 | 16
2 | 1. Lack of information on the comparative performance of PCA3 and currently used biomarkers to detect prostate cancer; lack of “matched studies” on comparators | What are the PCA3’s diagnostic performance characteristics in patients with elevated tPSA levels? | 7 | 15
3 | 1. Lack of information on the comparative performance of PCA3 and currently used biomarkers to detect prostate cancer; lack of “matched studies” on comparators | What is the comparative effectiveness of PCA3 compared to externally validated nomograms in predicting prostate biopsy results? | 5 | 12
4 | 1. Lack of information on the comparative performance of PCA3 and currently used biomarkers to detect prostate cancer; lack of “matched studies” on comparators | What is the comparative effectiveness of PCA3 compared to addition of PCA3 to externally validated nomograms in predicting prostate biopsy results? | 4 | 5
1 | 2. Lack of studies on how PCA3 actually helps in biopsy or treatment decisionmaking | Does the addition of PCA3, either alone or in combination with other markers, change prostate cancer biopsy or treatment decisionmaking for the patient or physician? | 8 | 12
1 | 2. Lack of studies on how PCA3 actually helps in biopsy or treatment decisionmaking | What information does PCA3 provide about the aggressiveness of prostate cancer? In other words, do positive results correlate to tumors with aggressive features on biopsy or upgrading of tumors on prostatectomy, and do negative results correlate to tumors that may not require identification or aggressive treatment? | 8 | 12