# Results From PCA3 Research Needs Prioritization Survey

Table F.1 Results from PCA3 future research needs prioritization survey

Rank | Research need | Total votes | Total Score
1 | Lack of information on the comparative performance of PCA3 and currently used biomarkers to detect prostate cancer; lack of “matched studies” on comparators | 4 | 11
2 | Lack of studies on how PCA3 actually helps in treatment decisionmaking | 4 | 8
3 | Lack of information on the impact of PCA3 on short term outcomes such as biopsy decisionmaking | 4 | 7
4 | Uncertainty of impact of PCA3 in biopsy decisionmaking on long-term health outcomes | 3 | 6
5 | Lack of a definition of “clinically significant improvement” in diagnostic accuracy | 2 | 5
6 | Potential for comparisons of PCA3 with tPSA to be affected by inadequate clinical characterization of populations studied (e.g. verification bias) | 3 | 4
6 | Lack of clear endpoint to establish performance; when PCA3 disagrees with other inclusion criteria how do you know which is right? | 2 | 4
7 | Lack of information on the impact of PCA3 in treatment decisionmaking on long-term health outcomes | 2 | 3
8 | Lack of information on how demographics impact PCA3 test | 0 | 0