# SurveyMonkey^®^ Form for Prioritizing PCA3 Research Needs

Please rank your top 3 research needs from 1 to 3, with 3 having the highest priority and 1 the lowest.

1. Lack of information on the comparative performance of PCA3 and currently used biomarkers to detect prostate cancer; lack of “matched studies” on comparators.
2. Lack of a definition of “clinically significant improvement” in diagnostic accuracy.
3. Potential for comparisons of PCA3 with tPSA to be affected by inadequate clinical characterization of populations studied (e.g., verification bias).
4. Lack of information on how demographics impact PCA3 test.
5. Lack of information on the impact of PCA3 on short term outcomes such as biopsy decisionmaking.
6. Uncertainty of impact of PCA3 in biopsy decisionmaking on long term health outcomes.
7. Lack of clear endpoint to establish performance; when PCA3 disagrees with other inclusion criteria; how do you know which is right?
8. Lack of studies on how PCA3 actually helps in treatment decisionmaking.
9. Lack of information on the impact of PCA3 in treatment decisionmaking on long-term health outcomes.