# Search Strategy for Recently Published and Ongoing Studies on PCA3 Testing

## PUBMED on 5/15/2012

(“prostate cancer antigen 3, human” [Supplementary Concept] OR “PCA3” OR “DD3” OR “DD3PCA3” OR “DD3(PCA3)” OR “prostate cancer gene 3” OR “prostate cancer antigen 3” OR “progensa” OR “differential display code 3”) AND (“prostate” OR “prostatic”)

Limits: English, Dates 8/1/2011 to 5/15/2012

Results: 31 citations

## EMBASE.COM on 5/15/2012

‘prostate cancer antigen 3, human’ OR pca3 OR dd3 OR dd3pca3 OR ‘dd3(pca3)’ OR ‘prostate cancer gene 3’ OR ‘prostate cancer antigen 3’ OR progensa OR ‘differential display code 3’ AND (‘prostate’/exp OR prostatic)

Limits: English, Dates 8/1/2011 to 5/15/2012

Results: 76 citations

## Cochrane Central on 5/15/2012

prostate cancer antigen 3 OR pca3 OR dd3 OR dd3pca3 OR dd3(pca3) OR prostate cancer gene 3 OR prostate cancer antigen 3 OR progensa OR differential display code 3’ AND (‘prostate’/exp OR prostatic)

Results: No new trials identified

## Clinical Trials.Gov

prostate cancer antigen 3 OR pca3 OR dd3 OR dd3pca3 OR dd3(pca3) OR prostate cancer gene 3 OR prostate cancer antigen 3 OR progensa

Results: 3 Newly updated trial records

## ASCO

prostate cancer antigen 3 OR pca3 OR dd3 OR dd3pca3 OR dd3(pca3) OR prostate cancer gene 3 OR prostate cancer antigen 3 OR progensa

Results: 3 2012 ASCO Conference Abstracts