# Conclusions From Draft Comparative Effectiveness Review of PCA3 for Detection and Treatment of Prostate Cancer

## Key Questions 1 and 2 Testing PCA3 and Comparators To Identify Men With Prostate Cancer in Initial or Repeat Biopsies

### Results and Strength of Evidence of PCA3 by Biopsy Status

Data was insufficient to evaluate PCA3 performance for key question 1 or 2 alone. Analysis of comparative matched PCA3:tPSA AUC curves and of performance at a pre-set PCA3 specificity of 50% indicated PCA3 performance did not appear to be affected by the biopsy status of patients. Therefore studies were combined and used to answer Key Questions 1 and 2 together.

### Results and Strength of Evidence of Comparison of PCA3 to tPSA

With regard to diagnostic accuracy, PCA3 was more discriminatory for detecting prostate cancer than extent of tPSA elevations. At any set clinical sensitivity, the clinical specificity of PCA3 testing is higher than that of tPSA. In addition, at any set clinical specificity, the clinical sensitivity of PCA3 was higher than that of tPSA. These two biomarkers appeared to be independent in detection of prostate. The strength of evidence for diagnostic accuracy was low.

With regard to the intermediate outcome of improved decisionmaking, PCA3 does have the potential to reduce unnecessary biopsies when compared to tPSA alone, by increasing the detection of true negative results and reducing potential harms of false positive results. However, no studies were identified that reported on this outcome. In addition, no studies were identified that addressed long-term outcomes (e.g., mortality, morbidity, quality of life) related to PCA3 and tPSA testing. The strength of evidence for these outcomes was insufficient.

### Results and Strength of Evidence of Comparison of PCA3 to Other Comparators

The data were missing or inadequate for comparison of PCA3 testing to the other selected biomarkers with regard to intermediate and long-term outcomes. The strength of evidence for all comparators was insufficient.

## Key Question 3 Testing PCA3 and Comparators To Identify Low Risk/Indolent Patients Who May Be Candidates for Active Surveillance

### Results and Strength of Evidence of PCA3 to Other Comparators

Estimation of diagnostic accuracy and assessment of intermediate outcomes (e.g., impact on decisionmaking and/or treatment harms) requires the use of a reference or gold standard. In this intended use, that would require a more long-term clinical endpoint or endpoints (e.g., measures of progression, metastasis, prostate cancer related morbidity), or a validated surrogate. Seven prospective studies of cohorts of men in active surveillance are currently ongoing. The one partially informative study in this review came from one of these groups. Median followup in these studies ranges from only two to seven years, so short term outcomes collected included percent progressing (i.e., increased grade/volume or PSA/PSA velocity) and time to progression.

More time will be needed for assessment of progression-free survival.20 Consequently, it is not surprising that no studies were identified that provided outcome information to support estimation of diagnostic accuracy or clinical impact of testing with PCA3 or comparators. The strength of evidence for all comparators and outcomes was insufficient.