# Results

## Research Needs

The FRN identification process led to the nomination of 16 topics (Table 3). We considered the 3 topics with endorsement by at least 50 percent of the stakeholders (with 8 of the 10 stakeholders voting) as the highest priority FRN topics. All three are based directly on evidence gaps identified in the CER.

Table 3 Nominated topics for future research needs for the SFLC assay in PCDs, according to rank^*^

Topic Rank^†^ | Topic Questions | No. of Stakeholder Votes
| Prioritized future research needs topics
1 | Context of treatment decisions, monitoring, and outcomes: What is the diagnostic performance of the SFLC assay either alone or in combination with traditional tests, compared with traditional tests alone, in detecting disease status in different treatment contexts (e.g., response and remission, relapse, and assessment of tumor burden)? [Alternate text: How accurately does the SFLC assay, compared with tests like electrophoresis or immunofixation, detect treatment response or relapse or disease activity?] | 4
2 | Context of treatment decisions, monitoring, and outcomes: How does the SFLC assay, either alone or in combination with traditional tests or as part of a definition of treatment response, compare with traditional tests in guiding treatment and management decisions (e.g., timing, duration, or type of treatment or use of adjunctive therapy or stem-cell transplantation) in patients with PCDs?; a. Do these comparisons differ by individual PCD populations?; b. How does the SFLC result, as a single result, change treatment or direct further investigation in individual PCDs?; c. What are suitable metrics (i.e., the best measurements) from the SFLC assay to make treatment decisions for PCD patients (e.g., absolute concentrations of the involved light chain [kappa or lambda], the absolute difference between the concentrations of the kappa and lambda chains, and the SFLC kappa-to-lambda ratio)?; d. What is the optimal frequency of monitoring with the SFLC assay with and without other tests for guiding management decisions by disease status and by PCD? | 5
3 | Context of reducing need for other testing: What is the role of the SFLC assay either alone or in combination with traditional tests, compared with traditional tests alone, in reducing the need for bone marrow examination by providing equivalent information for monitoring response to treatment, remission, or relapse in individual PCDs? | 4
| Other nominated future research needs topics
4 | Context of reducing need for other testing: What is the role of the SFLC assay either alone or in combination with traditional tests, compared with traditional tests alone, in reducing the need for 24-hour urine testing in detection of light chains by providing equivalent information:; a. for diagnosis of individual PCDs?; b. for monitoring response to treatment, remission, or relapse in individual PCDs? | 3
5@ | Context of current practice How are clinicians adopting the SFLC assay currently? Is the test an add-on or does it replace an existing, more complicated or more invasive test? If so, are practitioners cutting back on use of other tests (bone marrow biopsy, 24-hour urine) as a result? What is the current frequency of SLFC testing in patients with PCDs? | 3
6@ | Context of standardization of best practice: What are the “best practices” (both technical and clinical) for use of the SFLC assay in different populations with regard to:; a. laboratory testing (platform, lot, site) and reporting of results by laboratories; b. clinical use in diagnosis, monitoring, and/or prognosis; c. indication and prescribing/requisition patterns (e.g., frequency or timing of use) | 3
7 | Context of diagnostic testing: What is the diagnostic performance of the SFLC assay either alone or in combination with traditional tests, compared with traditional tests, in a high-risk population with regard to:; a. conditions such as antigen excess and polyclonal gammopathy (which can result in false negatives and false positives, respectively); b. diminished kidney function and the need for different reference ranges in kidney failure; c. technical variations in commercial assays, assay platform, or in house (hospital) vs. central lab testing; d. resolving discordant SFLC and traditional testing results in different PCDs; e. diagnostic reclassification based on SFLC testing | 2
8 | Context of diagnostic testing: What is the diagnostic performance of the SFLC assay either alone or in combination with traditional tests, compared with traditional tests, in individual PCDs with regard to:; a. conditions such as antigen excess and polyclonal gammopathy (which can result in false negatives and false positives, respectively); b. diminished kidney function and the need for different reference ranges in kidney failure; c. technical variations in commercial assays, assay platform, or in house (hospital) vs. central lab testing; d. resolving discordant SFLC and traditional testing results in different PCDs; e. diagnostic reclassification based on SFLC testing; f. detecting response and remission, relapse, and assessment of tumor burden; g. outcome prediction (response, disease-free survival, overall survival) | 2
9 | Context of MGUS progression to MM How well does the SFLC assay predict progression to MM in patients with MGUS?; a. What is its accuracy (strength of prediction as well as precision) as an independent predictor?; b. Can it diagnose or detect disease progression earlier than traditional tests?; c. Should the SFLC assay with or without other traditional testing be used in monitoring/surveillance and how often?; d. Are there variant populations of MGUS where the SFLC is more relevant to predict progression to MM?; e. What are suitable metrics (what are the best SFLC measurements) from the SFLC assay to predict progression of MGUS (e.g., absolute concentrations of the involved light chain [kappa or lambda], the absolute difference between the concentrations of the kappa and lambda chains, and the SFLC kappa-to-lambda ratio)? | 2
10 | Context of treatment decisions, monitoring, and outcomes What is the role of the SFLC assay, relative to other tests, in providing prognostic information?; a. How well does the SFLC assay predict outcomes such as treatment response, overall survival, or disease-free survival for individual PCD populations?; b. Does the test result in improved health outcomes?; c. What are suitable metrics from the SFLC assay to predict patient response and outcomes such as overall and disease-free survival (e.g., absolute concentrations of the involved light chain [kappa or lambda], the absolute difference between the concentrations of the kappa and lambda chains, and the SFLC kappa-to-lambda ratio)? | 2
11 | Context of reducing need for other testing: Can the frequency of current SIFE, SPEP, and UPEP testing be decreased if SFLC testing is added? | 2
12@ | Context of cost effectiveness: What is the cost effectiveness of using the SFLC assay as an add-on to other testing? | 2
13 | Context of diagnostic testing: What is the diagnostic performance of the SFLC assay either alone or in combination with traditional tests, compared with traditional tests, in the general population with regard to:; a. conditions such as antigen excess and polyclonal gammopathy (which can result in false negatives and false positives, respectively); b. diminished kidney function and the need for different reference ranges in kidney failure; c. technical variations in commercial assays, assay platform, or in house (hospital) vs. central lab testing; d. resolving discordant SFLC and traditional testing results in different PCDs; e. diagnostic reclassification based on SFLC testing | 1
14 | Context of treatment decisions, monitoring, and outcomes What is the role of the SFLC assay, relative to other tests, in managing patients who have undergone stem-cell transplantation? | 1
15@ | Context of cost effectiveness: What are the factors driving both raw costs and other expenditures (e.g., total cost of usage at a given institution) in the SFLC assay? Is the cost variation an issue related to SFLC assay or in house use vs. outsourcing? | 1
16@ | Context of newer tests: What are the newer tests available for the diagnosis, prognosis, and treatment monitoring of PCDs and how do they compare with the SFLC test with and without traditional tests? | 1

* Polyclonal gammopathy is seen in a diverse range of inflammatory and neoplastic diseases where clonal expansion occurs across various B-cell populations that produce more than one kind of immunoglobulin as part of a broad immune response unlike monoclonal gammopathy (or PCD) where a single neoplastic clone produces a single kind of immunoglobulin. Antigen excess is the condition in which SFLCs are present in great enough excess to form nonprecipitating immune complexes, which may alter the detection of the SFLCs and lead to inaccurate negative test results.

† Prioritized topics (1–3) are ordered logically by clinical content. Other nominated topics are listed in the order they were prioritized by the stakeholder panel.

@ Topics that were not addressed in the CER. Before initiating new research, a literature search and review is needed to confirm that any new research on the topic would not be duplicative.

Abbreviations: MGUS=monoclonal gammopathy of undetermined significance; MM=multiple myeloma; PCD=plasma cell dyscrasia; SFLC=serum free light chain; SIFE=serum immunofixation electrophoresis; SPEP=serum protein electrophoresis; UIFE=urine immunofixation electrophoresis; UPEP=urine protein electrophoresis.

The three top-ranked FRNs refer to the application of the SFLC assay in the contexts of diagnosis, treatment monitoring, and resource use. All three are of immediate and definitive clinical relevance and will impact the clinical management of patients with PCDs. Questions also emerged with respect to the diagnostic and prognostic role of the assay, especially in comparison with nontraditional testing. An example is the use of positron emission tomography to measure plasma cell tumor load.21 We assessed the potential of these issues for topic nomination, although none were top-rated.

The three top-ranked FRNs also have similar considerations for proposing a study design. The main reason for each topic being an evidence gap was a paucity of data, suggesting that a wide range of trial designs could be useful. A randomized controlled trial (RCT) would be ideal in all three cases, since RCTs inherently would yield the most robust and generalizable data, but the low prevalence of PCDs and severity of the disease in many patients requiring monitoring both make it unethical to consider a trial in which some patients are randomized to undergo a potentially useful test and others are randomized to forego the test. It would not be feasible or ethical to compare SFLC testing with traditional testing in a controlled fashion, as current practice includes both sets of tests in a diagnostic panel. Moreover, the variable severity and stages of the disease in a referral population adds to the complexity of conducting a trial. Therefore, we considered more feasible study designs and propose two for each of the three topics, as described below. The two designs are not intended to be mutually exclusive, but rather complementary.

### High-Priority Future Research Needs Topic 1

What is the diagnostic performance of the SFLC assay either alone or in combination with traditional tests, compared with traditional tests alone, in detecting disease status in different treatment contexts (e.g., response and remission, relapse, and assessment of tumor burden)?

#### Background

Insufficient evidence resulting from the lack of direct head-to-head comparisons regarding the diagnostic utility of the SFLC assay (vs. traditional tests) to inform treatment decisions led to the identification of this FRN topic from the SFLC CER. Key Question 4 of the CER was, “In patients with an existing diagnosis of PCD (MM, nonsecretory MM, or AL amyloidosis), is the SFLC assay better than traditional tests in indicating how the patient responds to treatment and of outcomes (overall survival, disease-free survival, remission, light chain escape, and quality of life)?” The CER included 11 studies in patients with AL amyloidosis and MM that evaluated the SFLC assay and traditional testing in parallel and examined their relationship to clinical outcomes in PCDs.15,22–30,31 No direct comparisons between the SFLC assay and traditional tests were performed. Three studies (all quality C) were conducted in patients with AL amyloidosis15,26, 28 and 8 (3 quality B; 5 quality C) in patients with MM.22–25,27,29–31 The CER found insufficient evidence for SFLC response as a better predictor of survival than M-protein response in both AL amyloidosis and in MM, as well as for the other outcomes specified. Although SFLC response to therapy appeared to be a consistent predictor of outcomes in AL amyloidosis, there was no evidence that the SFLC assay is superior to traditional tests, as direct comparisons were unavailable. Similarly, there was no evidence to ascertain whether SFLC response was a better predictor of outcomes than traditional tests in MM.

Building on research gaps identified from this Key Question, the aim of this FRN topic is to assess how accurately the SFLC assay, compared with traditional tests, detects treatment response, relapse, or disease activity.

Discussion among stakeholders related to several aspects of the use of the SFLC assay in the context of informing treatment. In consideration of the short half-life of light chains, stakeholders mentioned the potential ability of the assay to make a determination as to whether a specific therapy is working (possibly before traditional testing is able to). Another stakeholder was more cautious, noting that findings from a single test, particularly the SFLC assay, should not alone be used to change treatment, as its increased sensitivity may capture biochemical changes that are not clinically relevant. Other discussion mentioned adjunct tests, such as PET-CT in patients with nonsecretory MM, used with the SFLC assay to adjust treatment. Finally, one stakeholder proposed that a head-to-head study of treatment decisions, informed with and without SFLC results, could potentially be done to ascertain whether results of the assay would affect decisionmaking. However, across the board, stakeholders acknowledged the lack of information on the role of SFLC data to assess disease status.

#### Proposed Study Designs

Given the paucity of available evidence to completely answer important clinical questions relevant to the SFLC assay in the context of treatment decisions, monitoring, and outcomes, different study designs are reasonable. The following proposed study designs (Table 4) address the diagnostic performance of SFLC testing and traditional testing in detecting disease status in various treatment contexts but differ in terms of their feasibility.

Table 4 Potential research designs for topic 1

Considerations | Meta-Analysis of Individual Participant Data | Prospective Observational Study
Design description | Using completed or ongoing RCTs (e.g., STaMINA trial or others in Appendix B) or registry data as the source, where simultaneous SFLC and traditional testing has occurred, combine all treatment arms (within one or more RCTs or registry) into a single cohort of patients with a diagnosed PCD. Then ascertain the diagnostic accuracy of the SFLC assay against comparator(s), chosen a priori, to detect disease status in different treatment contexts (e.g., response and remission, relapse, or assessment of tumor burden). | Prospectively designed single-cohort studies consisting of patients receiving treatment (in the context of normal clinical practice) for a diagnosed PCD can be conducted to assess the diagnostic accuracy of the SFLC assay against comparator(s) to detect disease status in the different treatment contexts (e.g., response and remission, relapse, or assessment of tumor burden). Studies should have a priori calculation of the sample size needed for determination of the desired precision and should include inferences based on formal statistical testing of estimates of diagnostic accuracy.
Population | Patients with PCDs; each PCD could form a prespecified stratum or subgroup for analysis. | Patients with PCDs; each PCD could form a stratum or subgroup for analysis.
Intervention | SFLC testing and SFLC testing in combination with traditional testing. | SFLC testing and SFLC testing in combination with traditional testing.
Comparator | Traditional testing. | Traditional testing.
Outcomes | Measures of diagnostic accuracy (e.g., sensitivity, specificity, or predictive value) in different treatment contexts (e.g., response and remission, relapse, or assessment of tumor burden). | Measures of diagnostic accuracy (e.g., sensitivity, specificity, or predictive value) in different treatment contexts (e.g., response and remission, relapse, or assessment of tumor burden).
Timing | Trial duration/followup duration in cohorts or registries. | Trial duration/followup duration in cohorts.
Setting | Secondary analysis of preexisting data. | Prospective; clinical practice.
Advantages for producing a valid result | Benefits of large sample sizes and allowing for prespecified subgroup analyses but at the possible cost of bias from pooling varying patient groups; disadvantage of being a retrospective observational data analysis subject to inherent biases and limitations of component studies. | Relatively poor, given bias from lack of randomization.
Resource use, size, and duration | Resource use less than in an RCT but still moderate to high. Sample size not an issue, in spite of the relatively low prevalence of PCDs, because the cohorts would be from RCTs or registries. Duration would depend on acquisition of databases and subsequent analysis and would potentially be shorter than in a prospective cohort or clinical trial. | Resource use likely to be moderate. Size may be an issue due to low prevalence of PCDs. Study duration may vary due to natural history of condition.
Ethical, legal, and social issues | Meta-analysis uses existing data. With permission to use original study data, there should be no ethical issues. | Few ethical issues are likely to occur as the study involves components of normal patient care.
Availability of data/ability to recruit | Good; PCD is a rare disease but use of RCT or registry data would mitigate sample size limitations. | Poor, since PCD is a rare disease.

Abbreviations: PCD=plasma cell dyscrasia, RCT = randomized controlled trial, SFLC=serum free light chain.

### High-Priority Future Research Needs Topic 2

Context of treatment decisions, monitoring, and outcomes:

How does the SFLC assay, either alone or in combination with traditional tests or as part of a definition of treatment response, compare with traditional tests in guiding treatment and management decisions (e.g., timing, duration, or type of treatment or use of adjunctive therapy or stem-cell transplantation) in patients with PCDs?

a. Do these comparisons differ by individual PCD populations?
b. How does the SFLC result, as a single result, change treatment or direct further investigation in individual PCDs?
c. What are suitable metrics (i.e., the best measurements) from the SFLC assay to make treatment decisions for PCD patients (e.g., absolute concentrations of the involved light chain [kappa or lambda], the absolute difference between the concentrations of the kappa and lambda chains, and the SFLC kappa-to-lambda ratio)?
d. What is the optimal frequency of monitoring with the SFLC assay with and without other tests for guiding management decisions by disease status and by PCD?

#### Background

The SFLC CER revealed this topic as an evidence gap by finding insufficient evidence for one of the Key Questions that was similar to this topic:

“Key Question 3: In patients with an existing diagnosis of PCD (MM, nonsecretory MM, or AL amyloidosis), does the use of the SFLC assay result in different treatment decisions as compared with traditional tests? Does the use of the SFLC assay affect the management of patients by allowing for earlier institution of specific therapies? Does the use of the SFLC assay influence the duration of treatment? Does the use of the SFLC assay influence the type of treatment (e.g., radiation therapy)?”

We found no studies that formally compared the use of the SFLC assay with traditional tests to determine whether either led to different decisions with regard to timing, duration, or type of treatment. Although two studies described instances where SFLC testing was used for therapeutic decisionmaking, they were in largely uncontrolled settings and adequate inferential analysis was not possible.32,33 They did not fulfill the eligibility criteria for inclusion in the CER either. We therefore rated the strength of evidence as insufficient for this question.

Our stakeholders noted that the Key Question 3 was indeed a persistent evidence gap and remains a powerful question for both patients and providers, all of whom would like to understand the value of SFLC testing in the context of treatment and prognosis of PCDs. The degree of paraprotein reduction with treatment is one of the standard criteria used to define the completeness of hematologic response. Stakeholders indicated the need to both evaluate the independent role of SFLC testing and its role in comparison to other available tests that measure paraprotein. The biologic and other characteristics of the tumor often determine the type of paraprotein produced, which must be remembered while making the evaluation or comparison of the effectiveness of SFLC testing versus traditional testing across PCDs. The utility of SFLC testing in the context of treatment and prognosis will be predicated upon the significance of change in light chain production for disease response and outcome. Notwithstanding, SFLC testing has the highest sensitivity for detecting light chain production by tumors.

Bearing these aspects of SFLC testing in mind, the stakeholder panel offered additional qualifications to the original Key Question 3. They asked whether evaluation and comparison of SFLC testing with traditional testing would differ by individual PCD populations, with specific reference to MM, nonsecretory MM, or AL amyloidosis, and queried the value of a single SFLC result in changing treatment or directing further investigation in individual PCDs. There was also discussion about the best metrics applicable to the SFLC assay to make treatment decisions for PCD patients (e.g., absolute concentrations of the involved light chain [kappa or lambda], the absolute difference between the concentrations of the kappa and lambda chains, and the SFLC kappa-to-lambda ratio). Finally, an important aspect of SFLC testing was the definition for the optimal frequency of monitoring with and without other tests for guiding management decisions by disease status and by PCD.

#### Proposed Study Designs

Because the main reason for this topic being an evidence gap is a lack of systematically and methodically generated data, we considered feasible study designs based on secondary data analysis, including creative use of survey designs, and propose two here (Table 5). These two designs can be considered complementary. The first design addresses and compares the relationship between the results of SFLC testing and traditional testing to response definitions and treatment outcomes in an observational setting, using an individual patient data meta-analytic approach. The second design uses a survey using data from preexisting trials to query physicians blinded to the management or clinical outcome status of the patient to obtain their responses with respect to therapeutic decisionmaking.

Table 5 Potential research designs for topic 2

Considerations | Meta-Analysis of Individual Participant Data | Physician Surveys
Design description | Using completed or ongoing RCTs (e.g., the STaMINA trial in Appendix B) or registry data as the source, where simultaneous SFLC and traditional testing has occurred, combine all treatment arms (within one or more RCTs or registry) into a single cohort of patients with a diagnosed PCD. In this composite study population ascertain whether the SFLC assay is equivalent to the comparator chosen a priori for the definition or prediction of treatment response and outcomes pre-specified in the parent study. | Using data from completed or ongoing RCTs (e.g., the STaMINA trial in Appendix B) or cohort studies among patients with a diagnosed PCD who have had simultaneous SFLC and traditional testing, design surveys for physicians to indicate their responses to a set of patient data with regard to response status, and therapeutic approach in the absence and presence of the SFLC data. Physicians could also be randomized as to whether they are given SFLC results before or after traditional results? Patient data may be categorized by individual PCDs and clinical stage of the disease depending on primary study.
Population | Patients with PCDs; each PCD could form a prespecified stratum or subgroup for analysis | Physicians/providers.
Intervention | SFLC testing, metrics of SFLC testing, frequency of SFLC testing | SFLC testing.
Comparator | Traditional testing, metrics of traditional testing, frequency of traditional testing (prespecified reference categories) | Traditional testing.
Outcomes | Response to treatment, remission, relapse, and light chain escape; overall survival and disease-free survival | Diagnosis of response, remission or relapse; therapeutic approach proposed (timing, type and duration).
Timing | Trial duration/followup duration in cohorts or registries | Trial duration/follow up duration in cohorts or registries.
Setting | Secondary analysis of preexisting data | Patients with PCDs; each PCD could form a prespecified stratum or subgroup for analysis; clinical stage of the disease.
Advantages for producing a valid result | Benefits of large sample sizes and allowing for prespecified subgroup analyses but at the possible cost of bias from pooling varying patient groups; disadvantage of being a retrospective observational data analysis subject to inherent biases and limitations of component studies | Feasible and inexpensive; appropriate methods of randomization of both participants and patient data would reduce bias. Disadvantages inherent to survey methodology including inflexibility and subjectivity. Dependent on the percentage of respondents, quality of participation and responses and the quality of the survey tool used.
Resource use, size, and duration | Resource use less than in an RCT but still moderate to high. Sample size not an issue, in spite of the relatively low prevalence of PCDs, because the cohorts would be from RCTs or registries. Duration would depend on acquisition of databases and subsequent analysis and would potentially be shorter than in a prospective cohort or clinical trial | Resource use likely to be moderate; sample size would depend on number of respondents. Duration would depend on acquisition of databases and subsequent designing of survey and would potentially be shorter than a prospective cohort study or clinical trial.
Ethical, legal, and social issues | Would not be limiting | Would not be limiting.
Availability of data/ability to recruit | Good; PCD is a rare disease but use of RCT or registry data will mitigate sample size limitations | Dependent on number of respondents.

Abbreviations: PCD=plasma cell dyscrasia, RCT = randomized controlled trial, SFLC=serum free light chain

### High-Priority Future Research Needs Topic 3

What is the role of the SFLC assay either alone or in combination with traditional tests, compared with traditional tests alone, in reducing the need for bone marrow examination by providing equivalent information for monitoring response to treatment, remission, or relapse in individual PCDs?

#### Background

The SFLC CER revealed this topic as an evidence gap by finding insufficient evidence for one of the Key Questions that was a broader version of this topic, focused on any diagnostic testing, not only bone marrow biopsy: “Key Question 5: In patients with an existing diagnosis of PCD (MM, nonsecretory MM, or AL amyloidosis), does the use of the SFLC assay reduce the need for other diagnostic tests (e.g., bone marrow biopsy)?” Bone marrow examination is of particular interest because they can be cumbersome to perform and uncomfortable for patients, causing considerable noncompliance among physicians.

The evidence for this Key Question was deemed insufficient because only one small, retrospective cohort study) addressed the Key Question; it did, however, address bone marrow examination in particular as a gold standard and concluded that bone marrow examination could not be replaced by the SFLC assay.34 Specifically, the authors found that in 29 MM patients in whom the SFLC assay was performed, normalization of the SFLC ratio did not guarantee the achievement of complete remission on bone marrow examination (as defined by the gold standard of 5 percent or fewer plasma cells, 10 percent of patients with SFLC ratio normalization did not have complete remission). The study did not address the frequency of use of bone marrow examination for monitoring.

More information on this topic is anticipated from the results of the STaMINA trial of patients with light-chain MM (in which enrollment began in June 2010) by the Center for International Blood and Marrow Transplant Research (ClincialTrials.gov number NCT01109004; see Appendix B), which is prospectively collecting serum samples for light chain analysis (with normal levels required as part of a “stringent complete response” to treatment), along with flow-cytometry measurement of bone marrow and traditional tests for M protein.

Our stakeholders noted that this Key Question was indeed in and of itself an evidence gap and that it remained a powerful question for both patients and providers, all of whom would like to reduce the need for painful, expensive, invasive testing for the monitoring of response to treatment, remission, or relapse in patients with any PCD. Practitioners suggested that they did not anticipate that the SFLC would replace bone marrow biopsy for purposes of diagnosis at least, although it might reduce the need for biopsy later; one patient stakeholder gave anecdotal evidence that SLFC assay can be used alone in monitoring of the light-chain PCDs (nonsecretory MM, AL amyloidosis, or light chain MM).

Another reason for this being an evidence gap is that many of the available studies did not explicitly address comparative effectiveness of the SFLC assay versus traditional tests, instead of just clinical effectiveness of the SFLC assay.

#### Proposed Study Designs

We propose as two complementary study designs for this topic a prospective cohort study and a prospective observational study (Table 6).

Table 6 Potential research designs for topic 3

Considerations | Prospective Cohort Study | Prospective Observational Study
Design description | Using ongoing RCTs (e.g., the STaMINA trial in Appendix B) or registry data as the source, combine all treatment arms (within one RCT or registry) into a single cohort of patients with a diagnosed PCD with requirement of a complete response to therapy. In this cohort (or across multiple cohorts from multiple, comparable RCTs or registries), ascertain whether the SFLC assay is equivalent to the gold standard (as defined in the RCT or chosen a priori if registry data are used) of treatment response. | Patients with a diagnosed PCD with requirement of a complete response to therapy (not including normal SFLC results) as well as a stringent complete response (including normal SFLC results), with physicians surveyed about what treatment decisions would be in the absence and presence of the SFLC data. Alternative: SFLC done whenever bone marrow done by someone blinded (possible since tests are ordered, not done in office); physicians could be randomized as to whether they are given SFLC results before or after traditional results.
Population | Patients with PCDs. | Physicians/providers.
Intervention | SFLC testing. | SFLC testing.
Comparator | Bone marrow examination. | Bone marrow examination.
Outcomes | Measures of diagnostic accuracy, e.g., sensitivity, specificity, predictive value in different treatment contexts (e.g., response and remission, relapse, and assessment of tumor burden). Frequency of bone marrow examination. | Measures of diagnostic accuracy, e.g., sensitivity, specificity, predictive value in different treatment contexts (e.g., response and remission, relapse, and assessment of tumor burden). Frequency of bone marrow examination.
Timing | Trial duration/followup duration in cohorts or registries. | Trial duration/followup duration in cohorts or registries.
Setting | Prospective; clinical practice. | Prospective; clinical practice.
Advantages for producing a valid result | Arguably the optimal design when the treatment cannot ethically be assigned. Would carry most of the benefits of RCTs (or large registries) at the cost of possible bias from pooling of treatment arms. | Relatively poor, given bias due to lack of randomization and possible innate tendency of both physicians and patients to prefer more information to less.
Resource use, size, and duration | Resource use is less than in an RCT but still moderate to high. Size would not be an issue, in spite of the relatively low prevalence of PCDs, because the cohorts would be from RCTs or registries. Trial duration would be relatively short, since and the SLFC assay half-life is short (2 to 6 hours) and the median survival time is about 5 years. | Resource use is likely moderate. Size, and duration should not be an issue, since study would be observing normal clinical practice; sole difference is addition of SFLC assay for all patients rather than performed only at physician’s discretion, but assay is affordable (~$25 to $100, anecdotally) and covered by insurance.
Ethical, legal, and social issues | Ethical issues should not be an issue. | Ethical issues should not be an issue.
Availability of data/ability to recruit | Moderate; PCD is a rare disease but use of RCT or registry data should mitigate this. | Poor, since PCD is a rare disease.

Abbreviations: PCD=plasma cell dyscrasia, RCT = randomized controlled trial, SFLC=serum free light chain.