# References

1 Kyle RA, Rajkumar SV. Epidemiology of the plasma-cell disorders. Best Pract Res Clin Haematol. 2007;20:637-64. [pmid: 18070711].
2 Ries LAG, Harkins D, Krapcho M, et al. SEER cancer statistics review, 1975–2003. NCI. Bethesda, MD. 2005. Available at: http://seer.cancer.gov/csr/1975_2003. Accessed January 30, 2012.
3 Jemal A, Siegel R, Ward E, et al. Cancer Statistics, 2007. CA Cancer J Clin. 2007;57(1):43-66. [doi: 10.3322/canjclin.57.1.43]. [pmid: 17237035].
4 Katzel JA, Hari P, Vesole DH. Multiple myeloma: charging toward a bright future. CA Cancer J Clin. 2007;57(5):301-8. [doi: 10.3322/CA.57.5.301]. [pmid: 17855486].
5 Cook R. An economic perspective on treatment options in multiple myeloma. Managed Care Oncol. Spring. 2007:10-2.
6 Messori A, Trippoli S, Santarlasci B. Pharmacotherapy of multiple myeloma: an economic perspective. Expert Opin Pharmacother. Apr. 1. 2003;4(4):515-24. [doi: 10.1517/14656566.4.4.515]. [pmid: 12667114].
7 Kyle RA, Rajkumar SV. Criteria for diagnosis, staging, risk stratification and response assessment of multiple myeloma. Leukemia. 2009;23(1):3-9. [pmid: 18971951].
8 Palumbo A, Sezer O, Kyle R, et al. International Myeloma Working Group guidelines for the management of multiple myeloma patients ineligible for standard high-dose chemotherapy with autologous stem cell transplantation. Leukemia. Jun. 4. 2009;23(10):1716-30. [pmid: 19494840].
9 Rajkumar SV. Clinical features, laboratory manifestations, and diagnosis of multiple myeloma. Basow DS, editor. UpToDate. Waltham, MA. 2011.
10 Bradwell AR, Carr-Smith HD, Mead GP, et al. Highly sensitive, automated immunoassay for immunoglobulin free light chains in serum and urine. Clin Chem. Apr. 2001;47(4):673-80. [pmid: 11274017].
11 Rajkumar SV. Recognition of monoclonal proteins. Kyle RA, Connor RF, editors. UpToDate. Waltham, MA. 2011.
12 Katzmann JA. Serum free light chains: quantitation and clinical utility in assessing monoclonal gammopathies. Clin Lab News. Jun. 2006:12-4.
13 Dispenzieri A, Kyle R, Merlini G, et al. International Myeloma Working Group guidelines for serum-free light chain analysis in multiple myeloma and related disorders. Leukemia. Feb. 2009;23(2):215-24. [pmid: 19020545].
14 Mead GP, Carr-Smith HD, Drayson MT, et al. Serum free light chains for monitoring multiple myeloma. Br J Haematol. Aug. 2004;126(3):348-54. [pmid: 15257706].
15 Sanchorawala V, Seldin DC, Magnani B, et al. Serum free light-chain responses after high-dose intravenous melphalan and autologous stem cell transplantation for AL (primary) amyloidosis. Bone Marrow Transplant. Oct. 2005;36(7):597-600. [pmid: 16044137].
16 Kyle RA, Durie BGM, Rajkumar SV, et al. Monoclonal gammopathy of undetermined significance (MGUS) and smoldering (asymptomatic) multiple myeloma: IMWG consensus perspectives risk factors for progression and guidelines for monitoring and management. Leukemia. Jun. 2010;24(6):1121-7. [pmid: 20410922].
17 Bradwell AR. Serum free light chain measurements move to center stage. Clin Chem. May. 2005;51(5):805-7. [pmid: 15855664].
18 Whitlock EP, Lopez SA, Chang S, et al. AHRQ Series Paper 3: Identifying, selecting, and refining topics for comparative effectiveness systematic reviews: AHRQ and the Effective Health-Care program. J Clin Epidemiol. 2010;63:491-501. [pmid: 19540721].
19 Concannon T, Meissner P, Grunbaum J, et al. A new taxonomy for stakeholder engagement in patient-centered outcomes research. J Gen Intern Med. 2012:1-7. [pmid: 22086753].
20 Trikalinos TA, Dahabreh IJ, Wong J, et al. Future Research Needs for the Comparison of Percutaneous Coronary Interventions with Bypass Graft Surgery in Nonacute Coronary Artery Disease: Identification of Future Research Needs from Comparative Effectiveness Review No. 9. [Internet]. Rockville, MD. Agency for Healthcare Research and Quality. September. 2010. Available at: www.effectivehealthcare.ahrq.gov. Accessed January 30, 2012.
21 Elliott BM, Peti S, Osman K, et al. Combining FDG-PET/CT with laboratory data yields superior results for prediction of relapse in multiple myeloma. Eur J Haematol. Apr. 2011;86(4):289-98. [pmid: 21198866].
22 Dispenzieri A, Zhang L, Katzmann JA, et al. Appraisal of immunoglobulin free light chain as a marker of response. Blood. May. 15. 2008;111(10):4908-15. [pmid: 18364469].
23 Giarin MM, Giaccone L, Sorasio R, et al. Serum free light chain ratio, total kappa/lambda ratio, and immunofixation results are not prognostic factors after stem cell transplantation for newly diagnosed multiple myeloma. Clin Chem. Aug. 2009;55(8):1510-6. [pmid: 19520760].
24 Khoriaty R, Hussein MA, Faiman B, et al. Prediction of response and progression in multiple myeloma with serum free light chains assay: corroboration of the serum free light chain response definitions. Clin Lymphoma Myeloma Leuk. Feb. 2010;10(1):E10-3. [pmid: 20223721].
25 Kroger N, Asenova S, Gerritzen A, et al. Questionable role of free light chain assay ratio to determine stringent complete remission in multiple myeloma patients. Blood. Apr. 22. 2010;115(16):3413-4. [pmid: 20413663].
26 Kumar SK, Dispenzieri A, Lacy MQ, et al. Changes in serum-free light chain rather than intact monoclonal immunoglobulin levels predicts outcome following therapy in primary amyloidosis. Am J Hematol. Mar. 2011;86(3):251-5. [pmid: 21328431].
27 Kyrtsonis MC, Vassilakopoulos TP, Kafasi N, et al. Prognostic value of serum free light chain ratio at diagnosis in multiple myeloma. Br J Haematol. May. 2007;137(3):240-3. [pmid: 17408464].
28 Lachmann HJ, Gallimore R, Gillmore JD, et al. Outcome in systemic AL amyloidosis in relation to changes in concentration of circulating free immunoglobulin light chains following chemotherapy. Br J Haematol. Jul. 2003;122(1):78-84. [pmid: 12823348].
29 van RF, Bolejack V, Hollmig K, et al. High serum-free light chain levels and their rapid reduction in response to therapy define an aggressive multiple myeloma subtype with poor prognosis. Blood. Aug. 1. 2007;110(3):827-32. [pmid: 17416735].
30 Paiva B, Martinez-Lopez J, Vidriales MB, et al. Comparison of immunofixation, serum free light chain, and immunophenotyping for response evaluation and prognostication in multiple myeloma. J Clin Oncol. Apr. 20. 2011;29(12):1627-33. [pmid: 21402611].
31 Dytfeld D, Griffith KA, Friedman J, et al. Superior overall survival of patients with myeloma achieving very good partial response or better to initial treatment with bortezomib, pegylated liposomal doxorubicin, and dexamethasone, predicted after two cycles by a free light chain- and M-protein-based model: extended follow-up of a phase II trial. Leuk Lymphoma. Jul. 2011;52(7):1271-80. [pmid: 21699382].
32 Cohen AD, Zhou P, Chou J, et al. Risk-adapted autologous stem cell transplantation with adjuvant dexamethasone +/− thalidomide for systemic light-chain amyloidosis: results of a phase II trial. Br J Haematol. Oct. 2007;139(2):224-33. [pmid: 17897298].
33 Hutchison CA, Bradwell AR, Cook M, et al. Treatment of acute renal failure secondary to multiple myeloma with chemotherapy and extended high cut-off hemodialysis. Clin J Am Soc Nephrol JASN. Apr. 2009;4(4):745-54.
34 Chee CE, Kumar S, Larson DR, et al. The importance of bone marrow examination in determining complete response to therapy in patients with multiple myeloma. Blood. Sep. 24. 2009;114(13):2617-8. [pmid: 19641191].