# Methods

## Identification of Evidence Gaps

We used an iterative process with a stakeholder panel to identify FRN topics for prioritization. Building on evidence gaps identified in the original CER, the EPC generated an initial list of FRN topics (Table 1 above) and solicited additional topics from the stakeholder panel through conference calls and emails.

## Criteria for Prioritization

Stakeholders (described in the next section) were asked to consider four dimensions of need related to the proposed topic. These four dimensions come from the Effective Health Care Program selection criteria.

- Importance
  ○ Represents a significant disease burden, large proportion or priority population.
  ○ Is of high public interest; affects health care decisionmaking, outcomes, or costs for a large proportion of the U.S. population or for a priority population in particular.
  ○ Was nominated/strongly supported by one or more stakeholder groups.
  ○ Represents important uncertainty for decisionmakers.
  ○ Incorporates issues around both clinical benefits and potential clinical harms.
  ○ Represents important variation in clinical care, or controversy in what constitutes appropriate clinical care.
  ○ Represent high costs to consumers, patients, health care systems or payers; due to common use, high unit costs, or high associated costs.
- Desirability of research
  ○ Would not be redundant (i.e., the proposed topic is not already covered by available or soon-to-be available high quality systematic review by AHRQ or others).
- Feasibility
  ○ Effectively uses existing research and knowledge by considering adequacy of research for conducting a systematic review, and newly available evidence.
- Potential impact
  ○ Potential for significant health impact, significant economic impact, potential change, potential risk from inaction, addressing inequities and vulnerable populations, and/or addressing a topic with clear implications for resolving important dilemmas in health and health care decisions made by one or more stakeholder groups.

The fifth dimension of the selection criteria, appropriateness, was evaluated by EPC program staff after submission of initial FRN topics.

- Appropriateness:
  ○ Represents a health care drug, intervention, device, technology or health care system/setting available (or soon to be available) in the United States.
  ○ Relevant to 1013 enrollees (Medicare, Medicaid, CHIP, other Federal health care programs.
  ○ Represents one of the priority conditions designated by the U.S. Department of Health and Human Services (HHS).

Use of the Effective Health Care Program prioritization criteria was emphasized repeatedly throughout the prioritization process, including during discussion, nomination, and final topic selection. Upon the close of stakeholder prioritization, we identified the top five topics as those most frequently endorsed by stakeholders in their top five selections. The final ranked list was emailed to stakeholders.

To inform the selection criterion of desirability of research, as well as avoidance of unnecessary duplication, we prepared results of updated literature search in the ClinicalTrials.gov database and MEDLINE to identify ongoing and newly published studies that were not published at the time of the last CER update. Protocols of retrieved entries were reviewed for use of interventions and outcomes relevant to the Key Questions of the CER. The search strategy is provided in Appendix A and the identified studies are listed in Appendix B. The studies identified in the searches were compared against the nominated FRN topics to assess if they would make future research on any nominated topic redundant, but none appeared to do so.

## Engagement of Stakeholders, Researchers, and Funders

Although researchers and funders of research are the primary audience for FRN documents, the EPC solicits input from other stakeholders as well when identifying high-priority research gaps and FRN topics. Stakeholders are selected to provide broad expertise and a breadth of perspectives, as well as input on the kind of information that is helpful in health care decisionmaking. These stakeholders are engaged throughout the future research process. Their role is to (1) review the preliminary list of evidence gaps and possible future research topics derived from them, (2) to nominate additional topics to the list, (3) discuss topic nominations, and (4) participate in prioritization of the FRN topics. Stakeholders are not involved in translating the gaps into research questions and study designs or composing or reviewing the report.

### Prespecification of the Stakeholder Panel

We adapted a Tufts-developed “7Ps” model of stakeholder engagement to identify individuals from seven stakeholder categories.19 This model is designed to build a panel representing the full range of stakeholders who may use research evidence in health care and public health decisionmaking. The 7Ps are:

1. Patients and the public: This group represents current and potential consumers of patient-centered health care and population-focused public health research. This group also includes caregivers, family members, and patient advocacy organizations, all of whom represent the interests of consumers.
2. Providers: This group includes individuals (e.g., nurses, physicians, and other providers of care and support services) and organizations (e.g., hospitals, clinics, community health centers, community-based organizations, pharmacies, emergency medical services agencies, skilled nursing facilities, schools) that provide care to patients and populations.
3. Purchasers: This group includes employers, the self-insured, government, and other entities responsible for underwriting the costs of health care.
4. Payers: This group represents insurers, Medicare and Medicaid, individuals with deductibles, and others responsible for reimbursement for interventions and episodes of care.
5. Policymakers: This group includes organizations such as the White House, Health and Human Services, Congress, States, professional associations, and intermediary groups that collate and distribute information to policymakers.
6. Principal investigators, researchers, and research funders.
7. Product makers (i.e., drug and device manufacturers): representatives were asked to participate in the topic nomination process but not in topic refinement or final prioritization of topics.

These categories are not mutually exclusive. Any stakeholder may wear several hats and may be responsible for different types of decisions. For example, some health care purchasers are also payers; and conversely, some payers also provide care. Patients and their advocates may be providers or employers with policy-making responsibilities, and so on.

In addition, each of these seven stakeholder types may be focused on applying comparative effectiveness research at the patient level or at the population level. Patient-level decisions include questions pertaining to what treatment would be best for a given patient at a particular time. Population-level decisions include questions pertaining to what services, resources, policies, or other alternatives are best for groups of patients and entire communities that are connected by a practice setting, geography, clinical domain, or other cluster. To be patient-centered, decisions made about groups of patients must recognize both the diversity of needs across populations and the heterogeneity of individuals within populations. Each stakeholder was asked to make patient-centered recommendations, whether they represent a category that is focused on treating patients or on treating populations.

We designated a priori the numbers of stakeholders we would like to represent each group in our proposed stakeholder panel (Table 2), to achieve balance across stakeholder categories and to cover a range of technical and personal expertise in the group as a whole. We invited individuals who have previously served in advisory roles for the EPC’s SFLC CER. EPC team members also identified contacts in their professional networks. We conducted searches in Google, MEDLINE, Web of Science, and other publication databases as needed to identify active SFLC researchers to fill the provider and principal investigator categories.

Table 2 Prespecified composition of stakeholder panel for the SFLC future research needs document^*^

Category | Subcategory | No. of Stakeholders
Patients and the public | Current patients/patient advocates | 2
Providers | Clinician – Clinical Chemist/Nominator | 3
Providers | Clinician – Hematologist–Oncologist | 3
Providers | Clinician – Nurse practitioner | 3
Payers | Private insurer | 2
Payers | Centers for Medicare and Medicaid Services [Federal employee] | 2
Policymakers | Health Resources and Services Administration researcher | 1
Principal investigators/ researchers | Clinical researchers | 2
Product maker [nonvoting] | Binding Site Ltd. | 1^
TOTAL | | 11

Abbreviation: SFLC = serum free light chain.

* In the provider category, hospital administrators are an important provider subgroup but were not represented in this stakeholder panel because the SFLC assay is not a routine test in most hospitals. In the purchaser category, employers who purchase insurance policies were considered to share the payer perspective for this diagnostic test and therefore were not included as a separate stakeholder group.

^ Product maker was contacted to submit FRN topics but did not provide a response.

### Invitation and Solicitation of Topics

An invitation letter was sent to our candidates for representing each of the six stakeholder categories (excluding purchasers, for this project). To comply with the Paperwork Reduction Act requirements, the maximum number of nonfederal employee stakeholders is nine. All stakeholders completed a standard disclosure-of-interest form and were told that these forms would be made available to all other stakeholders. Along with the invitation letter, we distributed pertinent portions of the executive summary of the CER and a description of the FRN project to the invited stakeholders. The purpose of the project and expectations for input from the stakeholders were outlined clearly in the invitation letter. After the prespecified number of interested stakeholders was achieved in each category (Table 2), AHRQ’s Task Order Officer and the EPC jointly approved the panel.

The first round of Webinars, held in April and May 2012, served to introduce members, describe the purpose and process of FRN topic development, and review Key Questions and FRN topics proposed in the CER. During and after the first Webinar, stakeholders identified additional topics for nomination as well as comments. We synthesized these into the existing list of topics (including combining duplicate or similar FRN topics together into one topic). All but one stakeholder attended the first Webinar (held in replicate, on three different dates, to maximize participation), with one providing input by email in lieu of in-person participation.

Topics nominated by stakeholders were incorporated into the topic list along with supporting rationale, which we condensed from the discussion and subsequent emails. We combined duplicate or similar FRN topics together and disseminated the revised list of topics, along with the list of possibly relevant ongoing studies (Appendix B), with an invitation to comment as to whether the nominated topics and supporting rationales were appropriately recorded and accounted for.

These materials were sent to all stakeholders and discussed in the second set of Webinars, which were held (again in triplicate) in May 2012 to discuss the list and clarify or refine any of the topics. The topics could have included new questions identified during the conduct of the CER that could not be addressed in that context. Eight of the 10 stakeholders attended the second Webinar. There was no third set of Webinars for this project, although we offered to hold one as well as to hold subgroup or one-on-one calls as needed to accommodate stakeholder schedules and to allow all stakeholders to provide input.

Following this second round, we further edited the topic list on the basis of stakeholder rationale. We sent this, along with minutes from all the Webinars, back to stakeholders, who were given 1 week to provide comments by email. Following this commentary period, we finalized the list and asked stakeholders to electronically indicate their top five topic choices using an online application (Zoomerang) to ensure a complete, structured response and voting according to the AHRQ criteria for prioritization. The topics appeared in random order for each stakeholder to avoid selection bias. The topics with the highest number of stakeholder endorsements were designated as the prioritized FRN topics. Stakeholders from industry were not included in the prioritization process.

The EPC attempted to use natural breaks in the rankings of the topics across categories, rather than strictly defining the numbers of topics that fell into each category. The final ranked list was emailed to stakeholders.

## Research Question Development and Research Design Considerations

The EPC transformed the final list of FRN topics into answerable research questions using the standard “PICO-D” criteria (population, intervention, comparator, outcomes, study design). We discussed the pros and cons of various potential research designs and specifically considered the feasibility of the research questions focusing on potential sample size, time, and recruitment issues. To do so, we followed the structure laid out in the Future Research Needs for the Comparison of Percutaneous Coronary Interventions With Bypass Graft Surgery in Nonacute Coronary Artery Disease as a sample FRN document.20 As needed, the EPC consulted with individual stakeholders for assistance in making decisions regarding appropriate study designs.

Candidate study designs could differ across types of research needs. Effectiveness or efficacy of treatments are most definitively addressed in randomized trials and secondarily addressed in well-conducted nonrandomized comparative observational studies. In contrast, eliciting patient preferences can be meaningfully performed with nonexperimental designs (e.g., in a survey). Furthermore, observational studies may be most appropriate to enhance generalizability and determine effectiveness as opposed to efficacy alone. Each final FRN topic was assessed as to context of the research question and as to whether evaluation of efficacy or effectiveness is of greater need. Regardless of study design, PICO criteria were proposed.

Studies that do not require new data collection are in principle feasible, provided that access to existing data can be obtained or has already been granted. An analysis of an existing registry, a standard meta-analysis, or a meta-analysis of individual patient data can be conducted in a limited time frame. The feasibility of such studies generally does not depend on the desired sample size. The feasibility of trials (or other studies requiring accrual of primary data) may be infeasible if they are too expensive or complex to conduct, would require too long a followup, or would rely on information or data that is not yet available or would be difficult to obtain. It is important to note that randomized trials are among the most expensive research designs.