# Executive Summary

## Background

Plasma cell dyscrasias (PCDs) are a group of clonal disorders characterized by the uninhibited expansion of a monoclonal population of malignant plasma cells.1 Plasma cells arise from B cells in the bone marrow and produce immunoglobulins that constitute the body’s normal humoral immune response. The immunoglobulin molecule is composed of a heavy chain and a light chain. Plasma cells normally produce light chains in excess that do not bind to heavy chains to form a complete immunoglobulin molecule and instead enter the bloodstream as free light chains (FLCs). In PCDs, each abnormally expanded clone of malignant plasma cells produce an excess of either intact immunoglobulin or FLCs of a single type called a monoclonal protein (M-protein) or paraprotein.

The serum FLC (SFLC assay (the Freelite™ Assay, The Binding Site Ltd., Birmingham, United Kingdom) was introduced in 2001 to measure the FLC component in particular.2 The SFLC assay works by recognizing an epitope that is detectable only on light chains that are not bound to the heavy chain of the immunoglobulin molecule (i.e., FLCs) in the serum. This is the sole SFLC assay approved by the U.S. Food and Drug Administration. It detects low concentrations of FLCs and can measure the ratio of kappa chains to lambda chains.

It has been suggested that the SFLC assay could play an adjunctive role in screening, diagnosis, monitoring, and prognosis of PCDs in high-risk populations. The International Myeloma Working Group (IMWG) currently considers the SFLC assay to be an adjunct to traditional tests.3 The assay could allow for quantitative monitoring of response and remission after treatment and provide prognostic information,4,5 potentially reducing the need for frequent bone marrow biopsy for purposes of quantifying plasma cells, which is required as part of stringent monitoring for monoclonal gammopathy of undetermined significance (MGUS) progression to multiple myeloma (MM) or defining disease remission,3 and potentially could be used in conjunction with serum protein electrophoresis (SPEP) and serum immunofixation electrophoresis (SIFE) to replace urine tests that require 24-hour collection (urine protein electrophoresis [UPEP] and urine immunofixation electrophoresis [UIFE]), which could simplify diagnosis and disease monitoring.3,6 The SFLC assay may also be the only means of detecting a disease marker in some disease settings: nonsecretory MM, where SFLCs are often the only marker of the disease7; AL amyloidosis (systemic amyloidosis in which amyloid [A] proteins derived from immunoglobulin light chains [L] are deposited in tissue), where low monoclonal protein (M-protein) concentrations may not be detected by means of conventional techniques; and light chain MM, where the M-protein consists only of FLCs. These diagnostic applications have yet to be validated and standardized.8 Thus, although the SFLC assay has been in use for a decade, it remains unclear how best to incorporate it into clinical practice.9

The 2012 Agency for Healthcare Research and Quality (AHRQ) comparative effectiveness review (CER) upon which the current Future Research Needs (FRN) project is based (available at www.effectivehealthcare.ahrq.gov/ehc/products/264/900/Serum-Free-Light-Chain_Draft-Report_20111215.pdf) reviewed pertinent publications through April 2012 regarding the role of the SFLC assay in combination with traditional testing by electrophoresis and immunofixation, compared with traditional testing alone, in the diagnosis and management of patients with PCDs. This CER examined evidence addressing five Key Questions.

Key Question 1 Does adding the SFLC assay and the kappa/lambda ratio to traditional testing (SPEP, UPEP, SIFE, or UIFE), compared with traditional testing alone, improve the diagnostic accuracy for PCDs (MGUS, MM, nonsecretory MM, or AL amyloidosis) in undiagnosed patients suspected of having a PCD?
Key Question 2 As compared with traditional tests, how well does the SFLC assay independently predict progression to MM in patients with MGUS?
Key Question 3 In patients with an existing diagnosis of PCD (MM, nonsecretory MM, or AL amyloidosis), does the use of the SFLC assay result in different treatment decisions as compared with traditional tests?
  ○ Does the use of the SFLC assay affect the management of patients by allowing for earlier institution of specific therapies?
  ○ Does the use of the SFLC assay influence the duration of treatment?
  ○ Does the use of the SFLC assay influence the type of treatment (e.g., radiation therapy)?
Key Question 4 In patients with an existing diagnosis of PCD (MM, nonsecretory MM, or AL amyloidosis), is the SFLC assay better than traditional tests in indicating how the patient responds to treatment and of outcomes (overall survival, disease-free survival, remission, light chain escape, and quality of life)?
Key Question 5 In patients with an existing diagnosis of PCD (MM, nonsecretory MM, or AL amyloidosis), does the use of the SFLC assay reduce the need for other interventions (e.g., bone marrow biopsy)?

### Findings of the CER

Results and conclusions from the CER are based on 15 comparative studies, most of which were retrospective. Overall, because of the small number of studies and their low methodological quality and considerable clinical heterogeneity, the strength of evidence was rated as insufficient for the superiority of the combination of the SFLC assay and traditional testing over traditional testing alone: specifically, the SLFC assay’s impact on diagnostic accuracy in undiagnosed patients, as well as whether it is a better predictor of outcome or progression of MGUS to MM, a better indicator for therapeutic decisionmaking, or an appropriate substitute for other interventions.

### Evidence Gaps

Table A summarizes the evidence gaps identified in our review, organized according to whether they relate to the population, intervention, comparator, outcome or study design (PICO-D). There is considerable clinical uncertainty regarding the applications of the SFLC assay both within and beyond the 2009 IMWG consensus guidelines.3

Table A Evidence gaps affecting conclusions for the Key Questions

Key Questions | Evidence Gaps According to PICO Category
1. Does adding the SFLC assay and the kappa/lambda ratio to traditional testing (SPEP, UPEP, SIFE, or UIFE), compared with traditional testing alone, improve the diagnostic accuracy for PCDs (MGUS, MM, nonsecretory MM, or AL amyloidosis) in undiagnosed patients suspected of having a PCD? | Population:; - Lack of direct comparisons of the SFLC assay with traditional testing in undiagnosed patients suspected of having a PCD.; - Lack of studies of a nondiseased population as a comparison group (in order to accurately assess outcomes (e.g., false positives and true negatives).; ○ Studies of only patients with disease reflects the extreme end of the spectrum of disease severity and overestimates the proportion of patients with a positive result.; Intervention/Comparator:; - Lack of direct head-to-head comparisons of the SFLC assay alone with the SFLC assay plus traditional tests (e.g., to fully address whether SFLC measurement can replace UPEP or UIFE of 24-hour urine in diagnostic panels).; Outcome:; - Limited data regarding rates diagnostic accuracy of the SFLC assay.; ○ False positive rate in different settings.; ○ Effects of conditions such as polyclonal gammopathy or diminished kidney function on false positive rate; ○ Effects of factors such as antigen excess and technical variations in commercial assays on false negative rate.; - Lack of consensus on suitable gold standard for PCD diagnosis.; - Limited data on harms of testing.
2. As compared with traditional tests, how well does the SFLC assay independently predict progression to MM in patients with MGUS? | Population:; - None.; Intervention/Comparator:; - Lack of direct head-to-head comparisons of the SFLC assay with traditional tests to predict progression from MGUS to MM.; Outcome:; - Lack of consensus on suitable metrics from the SFLC assay to predict progression of MGUS (e.g., absolute concentrations of the involved light chain (kappa or lambda), the absolute difference between the concentrations of the kappa and lambda chains, and the SFLC kappa-to-lambda ratio).
3. In patients with an existing diagnosis of PCD (MM, nonsecretory MM, or AL amyloidosis), does the use of the SFLC assay result in different treatment decisions as compared with traditional tests? | Population:; - Lack of studies addressing the specific role of the SFLC assay in managing individual PCDs.; Intervention/Comparator:; - Lack of direct head-to-head comparisons of the SFLC assay and traditional tests (e.g., to fully address whether SFLC measurement can replace UPEP or UIFE of 24-hour urine in diagnostic panels to inform treatment decisions).; Outcome:; - Lack of consensus on suitable metrics from the SFLC assay to predict progression of diagnosed PCDs (e.g., absolute concentrations of the involved light chain (kappa or lambda), the absolute difference between the concentrations of the kappa and lambda chains, and the SFLC kappa-to-lambda ratio).; - Lack of studies of treatment decisions (including timing, duration, or type of treatment) based on results from the SFLC assay versus those from traditional tests.
4. In patients with an existing diagnosis of PCD (MM, nonsecretory MM, or AL amyloidosis), is the SFLC assay better than traditional tests in indicating how the patient responds to treatment and of outcomes (overall survival, disease-free survival, remission, light chain escape, and quality of life)? | Population:; - Lack of studies addressing the specific role of the SFLC assay in assessing response and outcomes for patients with individual PCDs; nonsecretory MM, light chain MM, or AL amyloidosis.; Intervention or Comparator:; - Lack of direct head-to-head comparisons of the SFLC assay and traditional tests regarding patient response (e.g., to fully address whether SFLC measurement can replace UPEP or UIFE of 24-hour urine in diagnostic panels to measure response to treatment).; Outcome:; - Lack of consensus on suitable metrics from the SFLC assay to predict patient response and outcome (e.g., absolute concentrations of the involved light chain (kappa or lambda), the absolute difference between the concentrations of the kappa and lambda chains, and the SFLC kappa-to-lambda ratio).
5. In patients with an existing diagnosis of PCD (MM, nonsecretory MM, or AL amyloidosis), does the use of the SFLC assay reduce the need for other interventions (e.g., bone marrow biopsy)? | Population:; - Lack of studies addressing the specific role of the SFLC assay in treatment decisions regarding individual PCDs: nonsecretory MM or AL amyloidosis.; Intervention/Comparator:; - Lack of direct head-to-head comparisons of the SFLC assay and traditional tests such as bone marrow biopsy or skeletal survey.; Outcome:; - Lack of consensus on suitable metrics from the SFLC assay to make treatment decisions for PCD patients (e.g., absolute concentrations of the involved light chain (kappa or lambda), the absolute difference between the concentrations of the kappa and lambda chains, and the SFLC kappa-to-lambda ratio).

Abbreviations: AL amyloidosis = systemic amyloidosis in which amyloid [A] proteins derived from immunoglobulin light chains [L] are deposited in tissue; IFE = immunofixation electrophoresis; MGUS = monoclonal gammopathy of undetermined significance; MM = multiple myeloma; PCD = plasma cell dyscrasia; PICO-D = population, intervention, comparator, outcome, and study design; SFLC = serum free light chain; SIFE = serum immunofixation electrophoresis; SPEP=serum protein electrophoresis; UIFE = urine immunofixation electrophoresis; UPEP=urine protein electrophoresis.

## Methods

Building on evidence gaps identified in the original CER (Table A above), the Evidence-based Practice Center (EPC) generated an initial list of FRN topics and solicited additional topics from a stakeholder panel (described below). Stakeholders were asked to consider four dimensions of need related to the proposed topic: importance, desirability of research, feasibility, and potential impact. These four dimensions come from the Effective Health Care Program Selection Criteria. The fifth dimension of the selection criteria, appropriateness, was evaluated by EPC program staff after submission of initial FRN topics. To inform the selection criterion of desirability of research, as well as avoidance of unnecessary duplication, we prepared results of an updated literature search in the ClinicalTrials.gov database and MEDLINE® to identify ongoing and newly published studies that were not published at the time of the last CER update. The studies identified in the searches were compared against the nominated FRN topics to assess if they would make future research on any nominated topic redundant, but none appeared to do so.

We adapted a Tufts-developed “7Ps” model of stakeholder engagement to identify individuals from seven stakeholder categories.10 We designated a priori 10 stakeholders we would like to make up our proposed stakeholder panel, according to the 7Ps: two current patients/advocates to represent patients and the public; three providers (a clinical chemist/nominator, a hematologist–oncologist, and a nurse practitioner; hospital administrators are an important provider subgroup but were not represented because the SFLC assay is not a routine test in most hospitals); 0 purchasers (employers who purchase insurance policies were considered to share the payer perspective for this diagnostic test and therefore were not included as a separate stakeholder group); two payers (one private insurer and one Centers for Medicare and Medicaid Services employee); one policymaker; two principal investigators, researchers, or research funders; and one nonvoting product maker. All stakeholders completed a standard disclosure-of-interest form. The product maker was also asked to propose topics but did not participate in the discussion and prioritization of the topics. After the prespecified number of interested stakeholders was achieved in each category, AHRQ’s Task Order Officer and the EPC jointly approved the panel.

The first round of Webinars was held in April and early May 2012. All but one stakeholder attended the first Webinar (held in replicate, on three different dates, to maximize participation), with one providing input by email in lieu of in-person participation. Taking the additional topics suggested by the stakeholder group during or immediately following the Webinars, we combined duplicate or similar FRN topics together and disseminated the revised list of topics, along with the list of possibly relevant ongoing studies (Appendix B), with an invitation to comment as to whether the nominated topics and supporting rationales were appropriately recorded and accounted for. These materials were sent to all stakeholders and discussed in the second set of Webinars, which were held (again in triplicate) in May 2012 to discuss the list and clarify or refine any of the topics. Eight of the 10 stakeholders attended the second Webinar. There was no third set of Webinars for this project, although we offered to hold one as well as to hold subgroup or one-on-one calls as needed. Following this second round, we further edited the topic list on the basis of stakeholder rationale. We sent this, along with minutes from all the Webinars, back to stakeholders, who were given 1 week to consider the input from stakeholders on other calls and to provide comments on research topics by email. Following this commentary period, we finalized the list and asked stakeholders to electronically indicate their top five topic choices using an online application (Zoomerang) to ensure a complete, structured response and voting according to the AHRQ criteria for prioritization. The topics appeared in random order for each stakeholder to avoid selection bias.

The topics with the highest number of stakeholder endorsements were designated as the prioritized FRN topics. The EPC transformed the final list of FRN topics into answerable research questions using the standard “PICO-D” criteria (population, intervention, comparator, outcomes, study design). We discussed the pros and cons of various potential research designs and specifically considered the feasibility of the research questions focusing on potential sample size, time, and recruitment issues. Candidate study designs could differ across types of research needs.

## Results

### Research Needs

The FRN identification process led to the nomination of 16 topics (Table B). We considered the three topics with endorsement by at least 50 percent of the stakeholders (with 8 of the 10 participating stakeholders voting) as the highest priority FRN topics. All three are based directly on evidence gaps identified in the CER.

Table B Nominated topics for future research needs for the SFLC assay in PCDs, according to rank^*^

Topic Rank^†^ | Topic Questions | No. of Stakeholder Votes
| Prioritized future research needs topics
1 | Context of treatment decisions, monitoring, and outcomes: What is the diagnostic performance of the SFLC assay either alone or in combination with traditional tests, compared with traditional tests alone, in detecting disease status in different treatment contexts (e.g., response and remission, relapse, and assessment of tumor burden)? [Alternate text: How accurately does the SFLC assay, compared with tests like electrophoresis or immunofixation, detect treatment response or relapse or disease activity?] | 4
2 | Context of treatment decisions, monitoring, and outcomes: How does the SFLC assay, either alone or in combination with traditional tests or as part of a definition of treatment response, compare with traditional tests in guiding treatment and management decisions (e.g., timing, duration, or type of treatment or use of adjunctive therapy or stem-cell transplantation) in patients with PCDs?; a. Do these comparisons differ by individual PCD populations?; b. How does the SFLC result, as a single result, change treatment or direct further investigation in individual PCDs?; c. What are suitable metrics (i.e., the best measurements) from the SFLC assay to make treatment decisions for PCD patients (e.g., absolute concentrations of the involved light chain [kappa or lambda], the absolute difference between the concentrations of the kappa and lambda chains, and the SFLC kappa-to-lambda ratio)?; d. What is the optimal frequency of monitoring with the SFLC assay with and without other tests for guiding management decisions by disease status and by PCD? | 5
3 | Context of reducing need for other testing: What is the role of the SFLC assay either alone or in combination with traditional tests, compared with traditional tests alone, in reducing the need for bone marrow examination by providing equivalent information for monitoring response to treatment, remission, or relapse in individual PCDs? | 4
| Other nominated future research needs topics
4 | Context of reducing need for other testing: What is the role of the SFLC assay either alone or in combination with traditional tests, compared with traditional tests alone, in reducing the need for 24-hour urine testing in detection of light chains by providing equivalent information:; a. for diagnosis of individual PCDs?; b. for monitoring response to treatment, remission, or relapse in individual PCDs? | 3
5@ | Context of current practice How are clinicians adopting the SFLC assay currently? Is the test an add-on or does it replace an existing, more complicated or more invasive test? If so, are practitioners cutting back on use of other tests (bone marrow biopsy, 24-hour urine) as a result? What is the current frequency of SLFC testing in patients with PCDs? | 3
6@ | Context of standardization of best practice: What are the “best practices” (both technical and clinical) for use of the SFLC assay in different populations with regard to:; a. laboratory testing (platform, lot, site) and reporting of results by laboratories; b. clinical use in diagnosis, monitoring, and/or prognosis; c. indication and prescribing/requisition patterns (e.g., frequency or timing of use) | 3
7 | Context of diagnostic testing: What is the diagnostic performance of the SFLC assay either alone or in combination with traditional tests, compared with traditional tests, in a high-risk population with regard to:; a. conditions such as antigen excess and polyclonal gammopathy (which can result in false negatives and false positives, respectively); b. diminished kidney function and the need for different reference ranges in kidney failure; c. technical variations in commercial assays, assay platform, or in house (hospital) vs. central lab testing; d. resolving discordant SFLC and traditional testing results in different PCDs; e. diagnostic reclassification based on SFLC testing | 2
8 | Context of diagnostic testing: What is the diagnostic performance of the SFLC assay either alone or in combination with traditional tests, compared with traditional tests, in individual PCDs with regard to:; a. conditions such as antigen excess and polyclonal gammopathy (which can result in false negatives and false positives, respectively); b. diminished kidney function and the need for different reference ranges in kidney failure; c. technical variations in commercial assays, assay platform, or in house (hospital) vs. central lab testing; d. resolving discordant SFLC and traditional testing results in different PCDs; e. diagnostic reclassification based on SFLC testing; f. detecting response and remission, relapse, and assessment of tumor burden; g. outcome prediction (response, disease-free survival, overall survival) | 2
9 | Context of MGUS progression to MM How well does the SFLC assay predict progression to MM in patients with MGUS?; a. What is its accuracy (strength of prediction as well as precision) as an independent predictor?; b. Can it diagnose or detect disease progression earlier than traditional tests?; c. Should the SFLC assay with or without other traditional testing be used in monitoring/surveillance and how often?; d. Are there variant populations of MGUS where the SFLC is more relevant to predict progression to MM?; e. What are suitable metrics (what are the best SFLC measurements) from the SFLC assay to predict progression of MGUS (e.g., absolute concentrations of the involved light chain [kappa or lambda], the absolute difference between the concentrations of the kappa and lambda chains, and the SFLC kappa-to-lambda ratio)? | 2
10 | Context of treatment decisions, monitoring, and outcomes What is the role of the SFLC assay, relative to other tests, in providing prognostic information?; a. How well does the SFLC assay predict outcomes such as treatment response, overall survival, or disease-free survival for individual PCD populations?; b. Does the test result in improved health outcomes?; c. What are suitable metrics from the SFLC assay to predict patient response and outcomes such as overall and disease-free survival (e.g., absolute concentrations of the involved light chain [kappa or lambda], the absolute difference between the concentrations of the kappa and lambda chains, and the SFLC kappa-to-lambda ratio)? | 2
11 | Context of reducing need for other testing: Can the frequency of current SIFE, SPEP, and UPEP testing be decreased if SFLC testing is added? | 2
12@ | Context of cost effectiveness: What is the cost effectiveness of using the SFLC assay as an add-on to other testing? | 2
13 | Context of diagnostic testing: What is the diagnostic performance of the SFLC assay either alone or in combination with traditional tests, compared with traditional tests, in the general population with regard to:; a. conditions such as antigen excess and polyclonal gammopathy (which can result in false negatives and false positives, respectively); b. diminished kidney function and the need for different reference ranges in kidney failure; c. technical variations in commercial assays, assay platform, or in house (hospital) vs. central lab testing; d. resolving discordant SFLC and traditional testing results in different PCDs; e. diagnostic reclassification based on SFLC testing | 1
14 | Context of treatment decisions, monitoring, and outcomes What is the role of the SFLC assay, relative to other tests, in managing patients who have undergone stem-cell transplantation? | 1
15@ | Context of cost effectiveness: What are the factors driving both raw costs and other expenditures (e.g., total cost of usage at a given institution) in the SFLC assay? Is the cost variation an issue related to SFLC assay or in house use vs. outsourcing? | 1
16@ | Context of newer tests: What are the newer tests available for the diagnosis, prognosis, and treatment monitoring of PCDs and how do they compare with the SFLC test with and without traditional tests? | 1

* Polyclonal gammopathy is seen in a diverse range of inflammatory and neoplastic diseases where clonal expansion occurs across various B-cell populations that produce more than one kind of immunoglobulin as part of a broad immune response unlike monoclonal gammopathy (or PCD) where a single neoplastic clone produces a single kind of immunoglobulin. Antigen excess is the condition in which SFLCs are present in great enough excess to form nonprecipitating immune complexes, which may alter the detection of the SFLCs and lead to inaccurate negative test results

† Prioritized topics (1–3) are ordered logically by clinical content. Other nominated topics are listed in the order they were prioritized by the stakeholder panel.

@ Topics that were not addressed in the CER. Before initiating new research, a literature search and review is needed to confirm that any new research on the topic would not be duplicative

Abbreviations: MGUS=monoclonal gammopathy of undetermined significance; MM=multiple myeloma; PCD=plasma cell dyscrasia; SFLC=serum free light chain; SIFE=serum immunofixation electrophoresis; SPEP=serum protein electrophoresis; UIFE=urine immunofixation electrophoresis; UPEP=urine protein electrophoresis

The three top-ranked FRNs refer to the application of the SFLC assay in the contexts of diagnosis, treatment monitoring, and resource use. All three are of immediate and definitive clinical relevance and will impact the clinical management of patients with PCDs.

The three also have similar considerations for proposing a study design. The main reason for each topic being an evidence gap was a paucity of data, suggesting that a wide range of trial designs could be useful. A randomized controlled trial (RCT) would be ideal in all three cases, since RCTs inherently would yield the most robust data, but the low prevalence of PCDs and severity of the disease in many patients requiring monitoring both make it unethical to consider a trial in which some patients are randomized to undergo a potentially useful test and others are randomized to forego the test and the heterogeneity of the PCD testing population may make it less generalizable. It would not be feasible or ethical to compare SFLC testing with traditional testing in a controlled fashion, as current practice includes both sets of tests in a diagnostic panel. Moreover, the variable severity and stages of the disease in a referral population adds to the complexity of conducting a trial. Therefore, we considered more feasible study designs and propose two for each of the three topics, as described below. The two designs are not intended to be mutually exclusive, but rather complementary.

### High-Priority Future Research Needs Topic 1

What is the diagnostic performance of the SFLC assay either alone or in combination with traditional tests, compared with traditional tests alone, in detecting disease status in different treatment contexts (e.g., response and remission, relapse, and assessment of tumor burden)?

Given the paucity of available evidence to completely answer important clinical questions relevant to the SFLC assay in the context of treatment decisions, monitoring, and outcomes, different study designs are reasonable. The following proposed study designs (Table C) address the diagnostic performance of SFLC testing and traditional testing in detecting disease status in various treatment contexts but differ in terms of their feasibility.

Table C Potential research designs for topic 1

Considerations | Meta-Analysis of Individual Participant Data | Prospective Observational Study
Design description | Using completed or ongoing RCTs (e.g., STaMINA trial or others) or registry data as the source, where simultaneous SFLC and traditional testing has occurred, combine all treatment arms (within one or more RCTs or registry) into a single cohort of patients with a diagnosed PCD. Then ascertain the diagnostic accuracy of the SFLC assay against comparator(s), chosen a priori, to detect disease status in different treatment contexts (e.g., response and remission, relapse, or assessment of tumor burden). | Prospectively designed single-cohort studies consisting of patients receiving treatment (in the context of normal clinical practice) for a diagnosed PCD can be conducted to assess the diagnostic accuracy of the SFLC assay against comparator(s) to detect disease status in the different treatment contexts (e.g., response and remission, relapse, or assessment of tumor burden). Studies should have a priori calculation of the sample size needed for determination of the desired precision and should include inferences based on formal statistical testing of estimates of diagnostic accuracy.
Population | Patients with PCDs; each PCD could form a prespecified stratum or subgroup for analysis. | Patients with PCDs; each PCD could form a stratum or subgroup for analysis.
Intervention | SFLC testing and SFLC testing in combination with traditional testing. | SFLC testing and SFLC testing in combination with traditional testing.
Comparator | Traditional testing. | Traditional testing.
Outcomes | Measures of diagnostic accuracy (e.g., sensitivity, specificity, or predictive value) in different treatment contexts (e.g., response and remission, relapse, or assessment of tumor burden). | Measures of diagnostic accuracy (e.g., sensitivity, specificity, or predictive value) in different treatment contexts (e.g., response and remission, relapse, or assessment of tumor burden).
Timing | Trial duration/followup duration in cohorts or registries. | Trial duration/followup duration in cohorts.
Setting | Secondary analysis of preexisting data. | Prospective; clinical practice.
Advantages for producing a valid result | Benefits of large sample sizes and allowing for prespecified subgroup analyses but at the possible cost of bias from pooling varying patient groups; disadvantage of being a retrospective observational data analysis subject to inherent biases and limitations of component studies. | Relatively poor, given bias from lack of randomization.
Resource use, size, and duration | Resource use less than in an RCT but still moderate to high. Sample size not an issue, in spite of the relatively low prevalence of PCDs, because the cohorts would be from RCTs or registries. Duration would depend on acquisition of databases and subsequent analysis and would potentially be shorter than in a prospective cohort or clinical trial. | Resource use likely to be moderate. Size may be an issue due to low prevalence of PCDs. Study duration may vary due to natural history of condition.
Ethical, legal, and social issues | Meta-analysis uses existing data. With permission to use original study data, there should be no ethical issues. | Few ethical issues are likely to occur as the study involves components of normal patient care.
Availability of data/ability to recruit | Good; PCD is a rare disease but use of RCT or registry data would mitigate sample size limitations. | Poor, since PCD is a rare disease.

Abbreviations: PCD=plasma cell dyscrasia, RCT = randomized controlled trial, SFLC=serum free light chain

### High-Priority Future Research Needs Topic 2

Context of treatment decisions, monitoring, and outcomes: How does the SFLC assay, either alone or in combination with traditional tests or as part of a definition of treatment response, compare with traditional tests in guiding treatment and management decisions (e.g., timing, duration, or type of treatment or use of adjunctive therapy or stem-cell transplantation) in patients with PCDs?

Because the main reason for this topic being an evidence gap is a lack of systematically and methodically generated data, we considered feasible study designs based on secondary data analysis, including creative use of survey designs, and propose two here (Table D). These two designs can be considered complementary.

Table D Potential research designs for topic 2

Considerations | Meta-Analysis of Individual Participant Data | Physician Surveys
Design description | Using completed or ongoing RCTs (e.g., the STaMINA trial) or registry data as the source, where simultaneous SFLC and traditional testing has occurred, combine all treatment arms (within one or more RCTs or registry) into a single cohort of patients with a diagnosed PCD. In this composite study population ascertain whether the SFLC assay is equivalent to the comparator chosen a priori for the definition or prediction of treatment response and outcomes pre-specified in the parent study. | Using data from completed or ongoing RCTs (e.g., the STaMINA trial) or cohort studies among patients with a diagnosed PCD who have had simultaneous SFLC and traditional testing, design surveys for physicians to indicate their responses to a set of patient data with regard to response status, and therapeutic approach in the absence and presence of the SFLC data. Physicians could also be randomized as to whether they are given SFLC results before or after traditional results? Patient data may be categorized by individual PCDs and clinical stage of the disease depending on primary study.
Population | Patients with PCDs; each PCD could form a prespecified stratum or subgroup for analysis. | Physicians/providers.
Intervention | SFLC testing, metrics of SFLC testing, frequency of SFLC testing. | SFLC testing.
Comparator | Traditional testing, metrics of traditional testing, frequency of traditional testing (prespecified reference categories). | Traditional testing.
Outcomes | Response to treatment, remission, relapse, and light chain escape; overall survival and disease-free survival. | Diagnosis of response, remission or relapse; therapeutic approach proposed (timing, type and duration).
Timing | Trial duration/followup duration in cohorts or registries. | Trial duration/follow up duration in cohorts or registries.
Setting | Secondary analysis of preexisting data. | Patients with PCDs; each PCD could form a prespecified stratum or subgroup for analysis; clinical stage of the disease.
Advantages for producing a valid result | Benefits of large sample sizes and allowing for prespecified subgroup analyses but at the possible cost of bias from pooling varying patient groups; disadvantage of being a retrospective observational data analysis subject to inherent biases and limitations of component studies. | Feasible and inexpensive; appropriate methods of randomization of both participants and patient data would reduce bias. Disadvantages inherent to survey methodology including inflexibility and subjectivity. Dependent on the percentage of respondents, quality of participation and responses and the quality of the survey tool used.
Resource use, size, and duration | Resource use less than in an RCT but still moderate to high. Sample size not an issue, in spite of the relatively low prevalence of PCDs, because the cohorts would be from RCTs or registries. Duration would depend on acquisition of databases and subsequent analysis and would potentially be shorter than in a prospective cohort or clinical trial. | Resource use likely to be moderate; sample size would depend on number of respondents. Duration would depend on acquisition of databases and subsequent designing of survey and would potentially be shorter than a prospective cohort study or clinical trial.
Ethical, legal, and social issues | Would not be limiting. | Would not be limiting.
Availability of data/ability to recruit | Good; PCD is a rare disease but use of RCT or registry data will mitigate sample size limitations. | Dependent on number of respondents.

Abbreviations: PCD=plasma cell dyscrasia, RCT = randomized controlled trial, SFLC=serum free light chain

### High-Priority Future Research Needs Topic 3

What is the role of the SFLC assay either alone or in combination with traditional tests, compared with traditional tests alone, in reducing the need for bone marrow examination by providing equivalent information for monitoring response to treatment, remission, or relapse in individual PCDs?

We propose as two complementary study designs for this topic a prospective cohort study and a prospective observational study (Table E).

Table E Potential research designs for topic 3

Considerations | Prospective Cohort Study | Prospective Observational Study
Design description | Using ongoing RCTs (e.g., the STaMINA trial or registry data as the source, combine all treatment arms (within one RCT or registry) into a single cohort of patients with a diagnosed PCD with requirement of a complete response to therapy. In this cohort (or across multiple cohorts from multiple, comparable RCTs or registries), ascertain whether the SFLC assay is equivalent to the gold standard (as defined in the RCT or chosen a priori if registry data are used) of treatment response. | Patients with a diagnosed PCD with requirement of a complete response to therapy (not including normal SFLC results) as well as a stringent complete response (including normal SFLC results), with physicians surveyed about what treatment decisions would be in the absence and presence of the SFLC data. Alternative: SFLC done whenever bone marrow done by someone blinded (possible since tests are ordered, not done in office); physicians could be randomized as to whether they are given SFLC results before or after traditional results.
Population | Patients with PCDs. | Physicians/providers.
Intervention | SFLC testing. | SFLC testing.
Comparator | Bone marrow examination. | Bone marrow examination.
Outcomes | Measures of diagnostic accuracy, e.g., sensitivity, specificity, predictive value in different treatment contexts (e.g., response and remission, relapse, and assessment of tumor burden). Frequency of bone marrow examination. | Measures of diagnostic accuracy, e.g., sensitivity, specificity, predictive value in different treatment contexts (e.g., response and remission, relapse, and assessment of tumor burden). Frequency of bone marrow examination.
Timing | Trial duration/followup duration in cohorts or registries. | Trial duration/followup duration in cohorts or registries.
Setting | Prospective; clinical practice. | Prospective; clinical practice.
Advantages for producing a valid result | Arguably the optimal design when the treatment cannot ethically be assigned. Would carry most of the benefits of RCTs (or large registries) at the cost of possible bias from pooling of treatment arms. | Relatively poor, given bias due to lack of randomization and possible innate tendency of both physicians and patients to prefer more information to less.
Resource use, size, and duration | Resource use is less than in an RCT but still moderate to high. Size would not be an issue, in spite of the relatively low prevalence of PCDs, because the cohorts would be from RCTs or registries. Trial duration would be relatively short, since and the SLFC assay half-life is short (2 to 6 hours) and the median survival time is about 5 years. | Resource use is likely moderate. Size, and duration should not be an issue, since study would be observing normal clinical practice; sole difference is addition of SFLC assay for all patients rather than performed only at physician’s discretion, but assay is affordable (~$25 to $100, anecdotally) and covered by insurance.
Ethical, legal, and social issues | Ethical issues should not be an issue. | Ethical issues should not be an issue.
Availability of data/ability to recruit | Moderate; PCD is a rare disease but use of RCT or registry data should mitigate this. | Poor, since PCD is a rare disease.

Abbreviations: PCD=plasma cell dyscrasia, RCT = randomized controlled trial, SFLC=serum free light chain

## Discussion

The three top-ranked FRNs referred to the application of the SFLC assay in the contexts of diagnosis, treatment monitoring, and resource use. These contexts echoed several of the Key Questions in the original CER, albeit with several differences.

The study designs we proposed were guided by two major considerations. First, we had to take into account the reality that the SFLC assay was already a test in regular and routine use for the management of PCDs and that many providers believed that it added value to patient care and helped in decisionmaking. Hence it was difficult to visualize a situation where it would be possible to randomize patients to care in the absence of performing the assay. Second, it was also crucial to avoid the very limitations that the CER identified in the studies evaluated for our original Key Questions. In addition, since both the CER and discussion with stakeholders revealed that SFLC results are complementary, not prescriptive on their own, we focused the study designs to capture clinical preferences, although we acknowledge that patient preference would be another avenue of study.

The process was not without limitations. We were able to obtain input from only 8 of the 10 members of our stakeholder panel, and the total number of stakeholders recruited was restricted, thus limiting representation. The threshold for distinguishing high-priority topics from the other topics in the final ranking was somewhat arbitrary, namely four or more votes (i.e., prioritization by 50 percent or more of the eight voters). Also, despite formal planning, the selection of stakeholders, solicitation of contributions, facilitation of discussion, and synthesis of suggestions remain, to some degree, idiosyncratic. There are as of yet no accepted standard methods by which to assess the validity of procedures to synthesize diverse stakeholder viewpoints.

## Conclusions

This report identifies three high-priority FRN topics to study the SFLC assay in PCD patients, which were identified by a stakeholder panel. These are all parts of or repeats of some of the CER Key Questions, for which there was little evidence. They are as follows:

1. Context of treatment decisions, monitoring, and outcomes: What is the diagnostic performance of the SFLC assay either alone or in combination with traditional tests, compared with traditional tests alone, in detecting disease status in different treatment contexts (e.g., response and remission, relapse, and assessment of tumor burden)? [Alternate text: How accurately does the SFLC assay, compared with tests like electrophoresis or immunofixation, detect treatment response or relapse or disease activity?]
2. Context of treatment decisions, monitoring, and outcomes: How does the SFLC assay, either alone or in combination with traditional tests or as part of a definition of treatment response, compare with traditional tests in guiding treatment and management decisions (e.g., timing, duration, or type of treatment or use of adjunctive therapy or stem-cell transplantation) in patients with PCDs?
  a. Do these comparisons differ by individual PCD populations?
  b. How does the SFLC result, as a single result, change treatment or direct further investigation in individual PCDs?
  c. What are suitable metrics (i.e., the best measurements) from the SFLC assay to make treatment decisions for PCD patients (e.g., absolute concentrations of the involved light chain [kappa or lambda], the absolute difference between the concentrations of the kappa and lambda chains, and the SFLC kappa-to-lambda ratio)?
  d. What is the optimal frequency of monitoring with the SFLC assay with and without other tests for guiding management decisions by disease status and by PCD?
3. Context of reducing need for other testing: What is the role of the SFLC assay either alone or in combination with traditional tests, compared with traditional tests alone, in reducing the need for bone marrow examination by providing equivalent information for monitoring response to treatment, remission, or relapse in individual PCDs?

## Abbreviations

AHRQ: Agency for Healthcare Research and Quality
AL amyloidosis: Systemic, or primary, amyloidosis in which amyloid [A] proteins derived from immunoglobulin light chains [L] are deposited in tissue (also called light-chain amyloidosis)
CER: Comparative Effectiveness Review
EPC: Evidence-based Practice Center
FLC: Free light chain
FRN: Future Research Needs
IMWG: International Myeloma Working Group
MGUS: Monoclonal gammopathy of undetermined significance
MM: Multiple myeloma
M-protein: Monoclonal protein (also called paraprotein)
PCD: Plasma cell dyscrasia
PICO (also PICOTS): Populations, interventions (diagnostic tests/disease monitoring), comparators, outcomes (and timing and settings)
RCT: Randomized controlled trial
SFLC: Serum free light chain
SIFE: Serum immunofixation electrophoresis
SPEP: Serum protein electrophoresis
UIFE: Urine immunofixation electrophoresis
UPEP: Urine protein electrophoresis

## References

1 Kyle RA, Rajkumar SV. Epidemiology of the plasma-cell disorders. Best Pract Res Clin Haematol. 2007;20:637-64. [pmid: 18070711].
2 Bradwell AR, Carr-Smith HD, Mead GP, et al. Highly sensitive, automated immunoassay for immunoglobulin free light chains in serum and urine. Clin Chem. Apr. 2001;47(4):673-80. [pmid: 11274017].
3 Dispenzieri A, Kyle R, Merlini G, et al. International Myeloma Working Group guidelines for serum-free light chain analysis in multiple myeloma and related disorders. Leukemia. Feb. 2009;23(2):215-24. [pmid: 19020545].
4 Mead GP, Carr-Smith HD, Drayson MT, et al. Serum free light chains for monitoring multiple myeloma. Br J Haematol. Aug. 2004;126(3):348-54. [pmid: 15257706].
5 Sanchorawala V, Seldin DC, Magnani B, et al. Serum free light-chain responses after high-dose intravenous melphalan and autologous stem cell transplantation for AL (primary) amyloidosis. Bone Marrow Transplant. Oct. 2005;36(7):597-600. [pmid: 16044137].
6 Katzmann JA. Serum free light chains: quantitation and clinical utility in assessing monoclonal gammopathies. Clin Lab News. Jun. 2006;June:12-4.
7 Kyle RA, Durie BGM, Rajkumar SV, et al. Monoclonal gammopathy of undetermined significance (MGUS) and smoldering (asymptomatic) multiple myeloma: IMWG consensus perspectives risk factors for progression and guidelines for monitoring and management. Leukemia. Jun. 2010;24(6):1121-7. [pmid: 20410922].
8 Rajkumar SV. Clinical features, laboratory manifestations, and diagnosis of multiple myeloma. Basow DS, editor. UpToDate. Waltham. UpToDate. 2011.
9 Whitlock EP, Lopez SA, Chang S, et al. AHRQ Series Paper 3: Identifying, selecting, and refining topics for comparative effectiveness systematic reviews: AHRQ and the Effective Health-Care program. J Clin Epidemiol. 2010;63:491-501. [pmid: 19540721].
10 Concannon T, Meissner P, Grunbaum J, et al. A new taxonomy for stakeholder engagement in patient-centered outcomes research. J Gen Intern Med. 2012:1-7. [pmid: 22086753].