# Acknowledgments

The authors gratefully acknowledge the stakeholders for their contributions to this project.