# Discussion

On the basis of the 2012 SFLC CER and our discussion with stakeholders, we identified 16 potential research areas, 3 of which were ranked as high-priority areas of future research. The recommendations for priority topics for future research were generated based on a stakeholder-driven nomination and review process. We followed the recently developed 7Ps taxonomy that was designed to aid researchers in the identification, recruitment, and engagement of stakeholders. Our stakeholder panel represented a broad range of perspectives, across all major stakeholder categories identified in this taxonomy.

Across the diversity of representation of different disciplines by stakeholders, a uniform consensus was the complementary role of the SFLC assay in the diagnosis and management of PCDs. Hence the need for future research was mainly directed toward optimizing the use of the assay in various contexts, patient groups, and disease stages.

The three top-ranked FRNs referred to the application of the SFLC assay in the contexts of diagnosis, treatment monitoring, and resource use. These contexts echoed several of the Key Questions in the original CER, albeit with several noteworthy differences. In the diagnostic context, emphasis was placed upon the diagnostic performance of the assay in detecting response, remission, and relapse and assessment of tumor burden in patients with diagnosed disease who are in some stage of therapeutic intervention and followup or disease management. Our original Key Questions addressed the use of the assay in patients with undiagnosed disease and there appeared to be a consensus among stakeholders that the assay had an adjunctive role to the established approach of needing a panel of tests to diagnose PCDs. In the context of therapeutic management of PCD, the prioritized FRN addressed the role of the SFLC assay in guiding treatment and management decisions. The scope of the research question appreciated the heterogeneous nature of PCDs and the likelihood that the application of the assay could differ by individual PCD. Finally, the context of utilizing the SFLC assay in a judicious way to reduce resource utilization, with specific reference to bone marrow examination, extended the understanding of its diagnostic role in patients with known PCD to define disease status such as response to treatment, remission, or relapse.

The study designs we proposed were guided by two major considerations. First, we had to take into account the reality that the SFLC assay was already a test in regular and routine use for the management of PCDs and that many providers believed that it added value to patient care and helped in decisionmaking. Hence it was difficult to visualize a situation where it would be possible to randomize patients to care in the absence of performing the assay. Second, it was also crucial to avoid the very limitations that the CER identified in the studies evaluated for our original Key Questions. Designs had to ensure adequate power to answer questions of interest and minimize biases. Study questions had to address the issues of heterogeneity of PCDs and be explicit and objective in the comparisons desired so that appropriate statistical testing could be applied. In addition, since both the CER and discussion with stakeholders revealed that SFLC results are complementary, not prescriptive on their own, we focused the study designs to capture clinical preferences, although we acknowledge that patient preference would be another avenue of study.

The process was not without limitations. We were able to obtain input from only 8 of the 10 members of our stakeholder panel, and the total number of stakeholders recruited was restricted, thus limiting representation. The threshold for distinguishing high-priority topics from the other topics in the final ranking was somewhat arbitrary, namely four or more votes (i.e., prioritization by 50 percent or more of the eight voters). Also, despite formal planning, the selection of stakeholders, solicitation of contributions, facilitation of discussion, and synthesis of suggestions remain, to some degree, idiosyncratic. There are as of yet no accepted standard methods by which to assess the validity of procedures to synthesize diverse stakeholder viewpoints. We believe that future methods work may be necessary to establish a formal process for validation, certification, and peer review of FRN rankings.