# Conclusions

This report identifies three high-priority FRN topics to study the SFLC assay in PCD patients, which were identified by a stakeholder panel. These are all parts of or repeats of some of the CER Key Questions, for which there was little evidence. They are as follows:

1. Context of treatment decisions, monitoring, and outcomes: What is the diagnostic performance of the SFLC assay either alone or in combination with traditional tests, compared with traditional tests alone, in detecting disease status in different treatment contexts (e.g., response and remission, relapse, and assessment of tumor burden)? [Alternate text: How accurately does the SFLC assay, compared with tests like electrophoresis or immunofixation, detect treatment response or relapse or disease activity?]
2. Context of treatment decisions, monitoring, and outcomes: How does the SFLC assay, either alone or in combination with traditional tests or as part of a definition of treatment response, compare with traditional tests in guiding treatment and management decisions (e.g., timing, duration, or type of treatment or use of adjunctive therapy or stem-cell transplantation) in patients with PCDs?
  a. Do these comparisons differ by individual PCD populations?
  b. How does the SFLC result, as a single result, change treatment or direct further investigation in individual PCDs?
  c. What are suitable metrics (i.e., the best measurements) from the SFLC assay to make treatment decisions for PCD patients (e.g., absolute concentrations of the involved light chain [kappa or lambda], the absolute difference between the concentrations of the kappa and lambda chains, and the SFLC kappa-to-lambda ratio)?
  d. What is the optimal frequency of monitoring with the SFLC assay with and without other tests for guiding management decisions by disease status and by PCD?
3. Context of reducing need for other testing: What is the role of the SFLC assay either alone or in combination with traditional tests, compared with traditional tests alone, in reducing the need for bone marrow examination by providing equivalent information for monitoring response to treatment, remission, or relapse in individual PCDs?