# Background

Plasma cell dyscrasias (PCDs) are a group of clonal disorders characterized by the uninhibited expansion of a monoclonal population of malignant plasma cells.1 Multiple myeloma (MM) is the most common malignant plasma cell tumor, accounting for about 1 percent of all cancer types,1 and the second most common hematologic malignancy in the United States. With an age-adjusted incidence rate of 5.5 cases per 100,000 population,2 the American Cancer Society estimated that there were 19,900 new diagnoses and 10,790 deaths due to myeloma in 2007.^3^ Although the median survival has improved to 5 years with current standards of treatment,4 the annual costs of modern therapies can range from $50,000 to $125,000 per patient.5,6

Plasma cells arise from B cells in the bone marrow and produce immunoglobulins that constitute the body’s normal humoral immune response. The immunoglobulin molecule is composed of a heavy chain and a light chain. Plasma cells normally produce light chains in excess that do not bind to heavy chains to form a complete immunoglobulin molecule and instead enter the bloodstream as free light chains (FLCs).

In PCDs, each abnormally expanded clone of malignant plasma cells produce an excess of either intact immunoglobulin or FLCs of a single type; either type of excess molecule is called a monoclonal protein (M-protein) or paraprotein. Measurement of M-proteins (either complete immunoglobulins or FLCs) is integral to diagnosing PCDs, monitoring disease response to therapy and adjusting treatment, and determining disease progression or relapse.

PCDs range in severity. The mildest and most common PCD is the precancerous monoclonal gammopathy of undetermined significance (MGUS), affecting approximately 3 percent of the general population 50 years of age or older. 1 MGUS can progress to asymptomatic MM (also called smoldering or indolent MM) or symptomatic MM. The M-proteins produced in MM are either intact immunoglobulins or FLCs or both. Rarer MM variants include light-chain MM (light chain MM, formerly known as Bence Jones myeloma), characterized by expanded FLC-producing clones, and oligosecretory or nonsecretory MM, in which few detectable light- or heavy-chain M-proteins are secreted. Other PCDs include systemic (primary) AL amyloidosis, also called light-chain amyloidosis (in which amyloid [A] proteins derived from immunoglobulin light chains [L] are deposited in tissue), as well as macroglobulinemia, solitary plasmacytoma, and plasma cell leukemia. AL amyloidosis can be a complication of MM but is often considered a distinct disorder related to a relatively stable, slow-growing plasma cell clone and organ dysfunction.

The International Myeloma Working Group (IMWG) recommends the following actions and tests for evaluation of a patient suspected of having a myeloma:7,8 a complete history taking and physical examination; routine laboratory testing including serum protein electrophoresis (SPEP), serum immunofixation electrophoresis (SIFE), nephelometric quantitation of immunoglobulins, and measurement of serum FLCs (SFLCs); bone marrow aspiration and biopsy with immunophenotyping, conventional cytogenetics, and fluorescence in situ hybridization; and imaging. Thus, testing for M-protein is only one part—albeit an integral part—of a suite of tests done to diagnose PCDs.

M-protein measurement and typing are traditionally achieved through the use of SPEP and/or urine protein electrophoresis (UPEP) and SIFE and/or urine immunofixation electrophoresis (UIFE), plus immunoglobulin quantification. These traditional tests have relatively low sensitivity, especially regarding concentrations of SFLCs. This lack of sensitivity leads to undetected cases of PCDs that involve excess FLCs. It is likely that up to 3 percent of cases of nonsecretory MM, light chain MM, or AL amyloidosis are not detected by traditional tests.9 To increase the chance of detection of FLCs in urine, 24-hour urine collection has been recommended, along with procedures to concentrate urine samples. Yet these adaptations can be cumbersome for patients and providers, affecting compliance and test accuracy.

The SFLC assay (Freelite™ Assay, The Binding Site Ltd., Birmingham, United Kingdom) was introduced in 2001 to measure the FLC component in particular.10 The SFLC assay works by recognizing an epitope that is detectable only on light chains that are not bound to the heavy chain of the immunoglobulin molecule (i.e., FLCs) in the serum. This is the sole SFLC assay approved by the U.S. Food and Drug Administration and is classified as an immunoglobulin light chain–specific immunological test system. It measures kappa and lambda light chains separately and detects low concentrations of FLCs—less than 1 mg/dL in serum and less than 200 mg/day in urine.11 The other main advantage is the ability to measure the ratio of kappa chains to lambda chains, for which the diagnostic range is 0.26–1.65.^12^ An abnormal ratio provides a useful index of clonality, as clonal disorders produce disproportionately high concentrations of a single type of light chain. In a given case of PCD, if kappa chains are in excess, the kappa/lambda ratio is greater than 1.65; if the lambda chains are in excess, the ratio is less than 0.26.

It has been suggested that the SFLC assay could play an adjunctive role in screening, diagnosis, monitoring, and prognosis of PCDs in high-risk populations. The IMWG currently considers the SFLC assay to be an adjunct to traditional tests. 13 The assay could allow for quantitative monitoring of response and remission after treatment and provide prognostic information,14,15 potentially reducing the need for frequent bone marrow biopsy for purposes of quantifying plasma cells, which is required as part of stringent monitoring for MGUS progression to MM or defining disease remission.13 It could also potentially be used in conjunction with SPEP and SIFE to replace urine tests that require 24-hour collection (UPEP and UIFE), which could simplify diagnosis and disease monitoring,12,13 although proper studies have yet to be undertaken to explore this potential benefit. The SFLC assay may also be the only means of detecting a disease marker in some disease settings: nonsecretory MM, where SFLCs are often the only marker of the disease16; AL amyloidosis, where low M-protein concentrations may not be detected by means of conventional techniques; and light chain MM, where the M-protein consists only of FLCs. Thus, in addition to detecting a wider spectrum of PCDs than traditional tests, the assay may help detect earlier stages of the disease, and because of the short half-life of SFLCs (2 to 6 hours, vs. 21 days for complete immunoglobulins17), the assay may also help detect relapses and treatment failures earlier than by reliance on M-protein concentrations alone. These diagnostic applications have yet to be validated and standardized. 9 Thus, although the SFLC assay has been in use for a decade, it remains unclear how best to incorporate it into clinical practice.18

The current Future Research Needs (FRN) project was launched upon the completion of an Agency for Healthcare Research and Quality (AHRQ) comparative effectiveness review (CER) and builds on the evidence gaps identified in that review. The present report describes the development of a stakeholder-prioritized list of research needs for the use of the SFLC assay in PCDs, along with a measured consideration of the advantages and disadvantages of various potential research designs, in order to help researchers and funders develop future research proposals or solicitations.

## Scope of the CER

The 2012 CER upon which the current FRN report is based, Serum Free Light Chain Analysis for the Diagnosis, Management, and Prognosis of Plasma Cell Dyscrasias (available at www.effectivehealthcare.ahrq.gov/ehc/products/264/900/Serum-Free-Light-Chain_Draft-Report_20111215.pdf) was sponsored by AHRQ and conducted by the Tufts Evidence-based Practice Center (EPC). It reviewed pertinent publications through April 2012 regarding the role of the SFLC assay in combination with traditional testing by electrophoresis and immunofixation, compared with traditional testing alone, in the diagnosis and management of patients with PCDs. This CER examined evidence addressing five Key Questions.

Key Question 1 Does adding the SFLC assay and the kappa/lambda ratio to traditional testing (SPEP, UPEP, SIFE, or UIFE), compared with traditional testing alone, improve the diagnostic accuracy for PCDs (MGUS, MM, nonsecretory MM, or AL amyloidosis) in undiagnosed patients suspected of having a PCD?
Key Question 2 As compared with traditional tests, how well does the SFLC assay independently predict progression to MM in patients with MGUS?
Key Question 3 In patients with an existing diagnosis of PCD (MM, nonsecretory MM, or AL amyloidosis), does the use of the SFLC assay result in different treatment decisions as compared with traditional tests?
  ○ Does the use of the SFLC assay affect the management of patients by allowing for earlier institution of specific therapies?
  ○ Does the use of the SFLC assay influence the duration of treatment?
  ○ Does the use of the SFLC assay influence the type of treatment (e.g., radiation therapy)?
Key Question 4 In patients with an existing diagnosis of PCD (MM, nonsecretory MM, or AL amyloidosis), is the SFLC assay better than traditional tests in indicating how the patient responds to treatment and of outcomes (overall survival, disease-free survival, remission, light chain escape, and quality of life)?
Key Question 5 In patients with an existing diagnosis of PCD (MM, nonsecretory MM, or AL amyloidosis), does the use of the SFLC assay reduce the need for other interventions (e.g., bone marrow biopsy)?

### Findings of the CER

Results and conclusions from the CER are based on 15 comparative studies. Three retrospective studies evaluated the SFLC assay as an adjunct to traditional testing in populations suspected of having a PCD. Three other retrospective studies of AL amyloidosis and eight studies of MM (six of which were retrospective) evaluated either baseline or post-treatment concentrations of SFLC or monoclonal protein as predictors of clinical outcomes. Finally, one study explored whether the use of the SFLC assay compared with traditional testing would reduce the need for bone marrow examination in assessing response to treatment.

Overall, because of the small number of studies and their low methodological quality and considerable clinical heterogeneity, the strength of evidence was rated as insufficient for the superiority of the combination of the SFLC assay and traditional testing over traditional testing alone: specifically, the SLFC assay’s impact on diagnostic accuracy in undiagnosed patients, as well as whether it is a better predictor of outcome or progression of MGUS to MM, a better indicator for therapeutic decisionmaking, or an appropriate substitute for other interventions.

Currently, there is a lack of sufficient evidence to determine whether the addition of the SFLC assay to traditional testing would increase the diagnostic accuracy of PCD or whether it would help prognosticate the disease course. Its precise role and optimal use across the spectrum of PCDs and clinical settings still needs to be defined. Potential areas where its benefit may be seen are in diagnosis and prognosis, monitoring of therapy, and aiding treatment decisions. Future research should focus on standardization of patient inclusion criteria, testing of diagnostic and disease monitoring algorithms, and defining outcome and response definitions. We discuss this in more detail in the next section.

## Evidence Gaps

Table 1 summarizes the evidence gaps identified in our review, organized according to whether they relate to the population, intervention, comparator, outcome or study design (PICO-D). There is considerable clinical uncertainty regarding the applications of the SFLC assay both within and beyond the 2009 IMWG consensus guidelines.13 Areas of uncertainty span the comparative effectiveness of the adjunctive role of the assay for the diagnosis of PCDs and the adjunctive and independent role of the assay in therapeutic decisions and monitoring, recognition of response and remission, and in predicting clinical outcomes and prognosis among patients with diagnosed PCDs. While comparative effectiveness was a common theme across all the CER’s Key Questions, clinical effectiveness is also a measure clinicians use to gauge the value of a test and therefore we applied this consideration for the purposes of identifying FRN topics. The currently available data do not completely answer important clinical questions relevant to patient management; further research is needed to help elucidate these issues.

Table 1 Evidence gaps affecting conclusions for the Key Questions

Key Questions | Evidence Gaps According to PICO Category
1. Does adding the SFLC assay and the kappa/lambda ratio to traditional testing (SPEP, UPEP, SIFE, or UIFE), compared with traditional testing alone, improve the diagnostic accuracy for PCDs (MGUS, MM, nonsecretory MM, or AL amyloidosis) in undiagnosed patients suspected of having a PCD? | Population:; - Lack of direct comparisons of the SFLC assay with traditional testing in undiagnosed patients suspected of having a PCD.; - Lack of studies of a nondiseased population as a comparison group (in order to accurately assess outcomes (e.g., false positives and true negatives).; ○ Studies of only patients with disease reflects the extreme end of the spectrum of disease severity and overestimates the proportion of patients with a positive result.; Intervention/Comparator:; - Lack of direct head-to-head comparisons of the SFLC assay alone with the SFLC assay plus traditional tests (e.g., to fully address whether SFLC measurement can replace UPEP or UIFE of 24-hour urine in diagnostic panels).; Outcome:; - Limited data regarding rates diagnostic accuracy of the SFLC assay.; ○ False positive rate in different settings.; ○ Effects of conditions such as polyclonal gammopathy or diminished kidney function on false positive rate; ○ Effects of factors such as antigen excess and technical variations in commercial assays on false negative rate.; - Lack of consensus on suitable gold standard for PCD diagnosis.; - Limited data on harms of testing.
2. As compared with traditional tests, how well does the SFLC assay independently predict progression to MM in patients with MGUS? | Population:; - None.; Intervention/Comparator:; - Lack of direct head-to-head comparisons of the SFLC assay with traditional tests to predict progression from MGUS to MM.; Outcome:; - Lack of consensus on suitable metrics from the SFLC assay to predict progression of MGUS (e.g., absolute concentrations of the involved light chain (kappa or lambda), the absolute difference between the concentrations of the kappa and lambda chains, and the SFLC kappa-to-lambda ratio).
3. In patients with an existing diagnosis of PCD (MM, nonsecretory MM, or AL amyloidosis), does the use of the SFLC assay result in different treatment decisions as compared with traditional tests? | Population:; - Lack of studies addressing the specific role of the SFLC assay in managing individual PCDs; Intervention/Comparator:; - Lack of direct head-to-head comparisons of the SFLC assay and traditional tests (e.g., to fully address whether SFLC measurement can replace UPEP or UIFE of 24-hour urine in diagnostic panels to inform treatment decisions).; Outcome:; - Lack of consensus on suitable metrics from the SFLC assay to predict progression of diagnosed PCDs (e.g., absolute concentrations of the involved light chain (kappa or lambda), the absolute difference between the concentrations of the kappa and lambda chains, and the SFLC kappa-to-lambda ratio).; - Lack of studies of treatment decisions (including timing, duration, or type of treatment) based on results from the SFLC assay versus those from traditional tests.
4. In patients with an existing diagnosis of PCD (MM, nonsecretory MM, or AL amyloidosis), is the SFLC assay better than traditional tests in indicating how the patient responds to treatment and of outcomes (overall survival, disease-free survival, remission, light chain escape, and quality of life)? | Population:; - Lack of studies addressing the specific role of the SFLC assay in assessing response and outcomes for patients with individual PCDs; nonsecretory MM, light chain MM, or AL amyloidosis.; Intervention or Comparator:; - Lack of direct head-to-head comparisons of the SFLC assay and traditional tests regarding patient response (e.g., to fully address whether SFLC measurement can replace UPEP or UIFE of 24-hour urine in diagnostic panels to measure response to treatment).; Outcome:; - Lack of consensus on suitable metrics from the SFLC assay to predict patient response and outcome (e.g., absolute concentrations of the involved light chain (kappa or lambda), the absolute difference between the concentrations of the kappa and lambda chains, and the SFLC kappa-to-lambda ratio).
5. In patients with an existing diagnosis of PCD (MM, nonsecretory MM, or AL amyloidosis), does the use of the SFLC assay reduce the need for other interventions (e.g., bone marrow biopsy)? | Population:; - Lack of studies addressing the specific role of the SFLC assay in treatment decisions regarding individual PCDs: nonsecretory MM or AL amyloidosis.; Intervention/Comparator:; - Lack of direct head-to-head comparisons of the SFLC assay and traditional tests such as bone marrow biopsy or skeletal survey.; Outcome:; - Lack of consensus on suitable metrics from the SFLC assay to make treatment decisions for PCD patients (e.g., absolute concentrations of the involved light chain (kappa or lambda), the absolute difference between the concentrations of the kappa and lambda chains, and the SFLC kappa-to-lambda ratio).

Abbreviations: AL amyloidosis = systemic amyloidosis in which amyloid [A] proteins derived from immunoglobulin light chains [L] are deposited in tissue; IFE = immunofixation electrophoresis; MGUS = monoclonal gammopathy of undetermined significance; MM = multiple myeloma; PCD = plasma cell dyscrasia; PICO-D = population, intervention, comparator, outcome, and study design; SFLC = serum free light chain; SIFE = serum immunofixation electrophoresis; SPEP=serum protein electrophoresis; UIFE = urine immunofixation electrophoresis; UPEP=urine protein electrophoresis.