# Lists of Ongoing Studies

Ongoing Research on the SFLC Assay in ClinicalTrials.gov as of July 7, 2012^*^

ClinicalTrials.gov Number | Title | Recruitment | Patient Population | Enrollment
NCT00089167 | Melphalan, Thalidomide, and Dexamethasone in Treating Patients With Newly Diagnosed, Previously Untreated Primary Systemic Amyloidosis | Completed | MM and plasma cell neoplasm | NR
NCT00301275 | Assessing Free Immunoglobulin Light Chains in Patients With Myeloma | Completed | MM | NR
NCT00416897 | Dexamethasone and Chemotherapy With or Without Plasma Exchange in Patients With Newly Diagnosed Multiple Myeloma and Acute Kidney Failure | Recruiting | MM and plasma cell neoplasm | 280
NCT00478075 | Samarium Sm 153 Lexidronam Pentasodium and Bortezomib in Treating Patients With Relapsed or Refractory Multiple Myeloma | Completed | MM and plasma cell neoplasm | 50
NCT00499577 | Stem Cell Transplant, Chemotherapy, and Biological Therapy in Treating Patients With High-Risk or Refractory Multiple Myeloma | Completed | MM and plasma cell neoplasm | 56
NCT00621400 | Lenalidomide in Combination With Melphalan and Dexamethasone in Newly-diagnosed Light-chain (AL)-Amyloidosis | Completed | Amyloidosis | 27
NCT00910078 | Serum Free Light Change in Multiple Myeloma | Completed | MM | NR
NCT00972712 | Protocol of the Combination of Bortezomib and Tipifarnib for Relapsed or Refractory Multiple Myeloma | Active, not recruiting | MM | 35
NCT00637767 | High-Dose Melphalan With or Without Radiolabeled Monoclonal Antibody in Treating Patients With Multiple Myeloma Undergoing an Autologous Stem Cell Transplant | Recruiting | MM and plasma cell neoplasm | 90
NCT00681044 | High-Dose Melphalan and Stem Cell Transplant in Treating Patients With Immunoglobulin Deposition Disease or Light-Chain Deposition Disease | Recruiting | MM and plasma cell neoplasm | 30
NCT00821301 | Study of Fluphenazine in Relapsed or Relapsed-and-Refractory Multiple Myeloma | Recruiting | MM | 30
NCT00881920 | Autologous T Lymphocytes Engrafted With a Chimeric Antigen Receptor Targeting the Kappa Light Chain | Recruiting | Lymphoma Myeloma Leukemia | 18
NCT01084837 | Study of Induction Treatment With Velcade and Dexamethasone for Previously Untreated Patients With Multiple Myeloma and Renal Failure | Recruiting | MM | 60
NCT01194791 | Lendexal in Patients With Primary Systemic Amyloidosis (AL) Newly Diagnosed | Recruiting | Primary systemic amyloidosis | 30
NCT01208818 | Studies in Patients With Multiple Myeloma and Renal Failure Due to Myeloma Cast Nephropathy | Recruiting | Chronic renal failure with uremic nephropathy | 284
NCT01277016 | A Trial for Systemic Light-chain (AL) Amyloidosis | Recruiting | AL amyloidosis | 110
NCT01383759 | Bortezomib/Dexamethasone (BD), Followed By Autologous Stem Cell Transplantation and Maintenance Bortezomib/Dexamethasone For the Initial Treatment of Monoclonal Immunoglobulin Deposition Disease (MIDD) Associated With Multiple Myeloma and AL Amyloidosis | Recruiting | Light chain and heavy chain deposition disease Monoclonal Immunoglobulin deposition disease Amyloidosis | 35
NCT01423344 | Clinical Evaluation of the Serum Free Light Chain Analysis | Recruiting | MM | 30
NCT01109004^**^ | Stem Cell Transplant With Lenalidomide Maintenance in Patients With Multiple Myeloma (BMT CTN 0702) | Recruiting | MM | 750
NCT00120263 | Trial of Plasma Exchange for Acute Renal Failure at the Onset of Myeloma | Completed | MM Acute Renal Failure | 92
NCT00135187 | Study of Combination Therapy With VELCADE, Doxil, and Dexamethasone (VDd) in Multiple Myeloma | Completed | MM | 30
NCT00344526 | Intensive Versus Conventional Treatment in Patients With Primary Amyloidosis | Completed | Primary systemic amyloidosis | 100
NCT00726466 | Study of Efalizumab Combined With Intravitreal Ranibizumab in the Treatment of Age-Related Macular Degeneration | Withdrawn | AMD CNV | 10
NCT00787969 | Rituximab, Cladribine, and Temsirolimus in Treating Patients With Newly Diagnosed Mantle Cell Lymphoma | Active, not recruiting | Lymphoma | 74
NCT00981097 | Study of Blood and Tissue Samples From Patients With Aggressive Non-Hodgkin B-Cell Lymphoma or Hodgkin Lymphoma | Recruiting | Lymphoma Nonneoplastic Condition | 50
NCT01067313 | Continuous Hemodialysis With an Enhanced Middle Molecule Clearance Membrane | Completed | Septic Shock | 24
NCT01237054 | Imaging in MGUS, SMM and MM | Completed | MM Smoldering MM MGUS | 31
NCT01308073 | Stability of Middle Molecule Clearance | Recruiting | Continuous Hemodialysis | 15
NCT01541527 | Non Neutralizing Antibodies: Prevalence and Characterization | Recruiting | Hemophilia A | 300

Abbreviations: AL amyloidosis = systemic amyloidosis in which amyloid [A] proteins derived from immunoglobulin light chains [L] are deposited in tissue, AMD = Age-Related Macular Degeneration, CNV = choroidal neovascularization, MGUS = Monoclonal Gammopathy of Undetermined Significance, MM = multiple myeloma, NR = not reported.

* Search terms were as follows: [Immunoglobulin Light Chain* OR monoclonal light chain* OR serum free light chain* OR immunoglobulin-free light chain* OR Bence Jones protein*]. We also conducted a search of published randomized controlled trials but did not find any of interest that were published after the CER was completed.

** Identified by a reviewer of the SFLC comparative effectiveness review rather than through this ClinicalTrials.gov search. After adding this, because it was not captured in search, we ran an alternative search strategy crossing four new terms (Multiple myeloma* OR Plasma cell neoplasms* OR Amyloidosis* OR Paraproteinemias*) with the original terms (Immunoglobulin Light Chain* OR monoclonal light chain* OR serum free light chain* OR immunoglobulin-free light chain* OR Bence Jones protein*). This alternative search yielded only 23 studies—less than the updated original and still missing the NCT01109004 study. Thus we report the results of our original search in this table.