# Search Strategy for Ongoing Studies

Databases: Ovid MEDLINE(R) In-Process & Other Non-Indexed Citations <January 31, 2012>, EBM Reviews - Cochrane Database of Systematic Reviews <2005 to January 31, 2012>, EBM Reviews - Cochrane Central Register of Controlled Trials <1st Quarter 2012>, Ovid MEDLINE(R) without Revisions <1996 to January Week 4 2012>

Last run 1/31/2012

1. Immunoglobulin Light Chain*.mp. or exp Immunoglobulin Light Chains/
2. monoclonal light chain*.mp.
3. serum free light chain*.mp.
4. immunoglobulin-free light chain*.mp.
5. Bence Jones protein.mp. or exp Bence Jones Protein/
6. 1 or 2 or 3 or 4 or 5
7. limit 6 to English language [Limit not valid in the Cochrane databases; records were retained]
8. limit 7 to yr=“2000 -Current”
9. remove duplicates from 8