# Abbreviations

AHRQ: Agency for Healthcare Research and Quality
AL amyloidosis: Systemic, or primary, amyloidosis in which amyloid [A] proteins derived from immunoglobulin light chains [L] are deposited in tissue (also called light-chain amyloidosis)
CER: Comparative Effectiveness Review
EPC: Evidence-based Practice Center
FLC: Free light chain
FRN: Future Research Needs
IMWG: International Myeloma Working Group
MGUS: Monoclonal gammopathy of undetermined significance
MM: Multiple myeloma
M-protein: Monoclonal protein (also called paraprotein)
PCD: Plasma cell dyscrasia
PICO (also PICOTS): Populations, interventions (diagnostic tests/disease monitoring), comparators, outcomes (and timing and settings)
RCT: Randomized controlled trial
SFLC: Serum free light chain
SIFE: Serum immunofixation electrophoresis
SPEP: Serum protein electrophoresis
UIFE: Urine immunofixation electrophoresis
UPEP: Urine protein electrophoresis