# Results

## Engagement of Stakeholders, Researchers, and Funders

A total of 13 stakeholders (2 Federal, 11 non-Federal) representing the perspective of patient advocacy groups, academic researchers, obstetricians and gynecologists, nursing and nurse-midwifery professional organizations, the payor perspective, and national foundations and societies agreed to participate in one or more of the stages of ranking and prioritization. The group includes five Key Informants/Technical Expert Panel members from the draft CER. Throughout the teleconferences and surveys, stakeholder participation varied from 69 percent to 84 percent. Figure 4 presents stakeholder recruitment and participation results.

Figure 4 Stakeholder recruitment and participation results

Figure 4 is a flowchart that outlines the results of stakeholder recruitment and levels of stakeholder participation throughout the prioritization phase of the project. It begins with the total number of individuals invited to participate in the project (24 stakeholders) and ends with the number and percentage of stakeholders who completed the final round of prioritization (9, 69%). The figure is described further in the Section entitled “Results” as follows: “A total of 13 stakeholders (2 federal, 11 nonfederal) representing the perspective of patient advocacy groups, academic researchers, obstetricians and gynecologists, nursing and nurse-midwifery professional organizations, the payor perspective, and national foundations and societies agreed to participate in one or more of the stages of ranking and prioritization. The group includes five Key Informants/Technical Expert Panel members from the draft CER. Throughout the teleconferences and surveys, stakeholder participation varied from 69% to 84%.”

## Identification of Evidence Gaps

In Phase 1, the EPC investigators started with the 17 evidence gaps identified in the draft review and translated these gaps into a list of 12 sample research questions and 12 sample methodologic recommendations that have potential utility for reducing cesarean birth. We invited the stakeholder panel to participate in a teleconference and then a web-based survey to make the list broader and more comprehensive and to suggest topics we may have omitted.

During the teleconference and snowballing survey, stakeholders expanded the initial list to 47 research questions and 17 methodologic recommendations. These items encompassed a wide range of topics and are presented in Tables 3–4. Figure 5 shows the snowballing process and results for Phase 1.

Table 3 Snowballed list of research questions

Research Questions
1. Why do some patients prefer to undergo elective cesarean?
2. What factors drive a patient's decision to undergo a primary cesarean during labor, e.g. prior cesarean, general fears, fear of future pelvic floor disorders?
3. What patient preferences influence decisions to convert to primary cesarean during labor, e.g. pain management, progress of labor, fears about fetal well-being?
4. What physician factors contribute to use of elective cesarean, e.g. residency training, attitude toward elective cesarean, practice size, practice setting, shift/time of day, use of hospitalists, personal birth experience?
5. What physician factors contribute to use of cesarean during labor, e.g. residency training, attitude toward elective cesarean, practice size, practice setting, shift/time of day, use of hospitalists, personal birth experience?
6. To what extent do nonfinancial incentives such as time savings, control, and perceived improvement in patient relations affect physician decisions to use cesarean?
7. What nurse or midwife factors contribute to the use of cesarean during labor?
8. What nurse or midwife factors contribute to the use of elective cesarean?
9. What hospital factors contribute to the use of cesarean during labor, e.g. teaching status, geographical region, urban location, socioeconomic status of patients, staffing and scheduling patterns, provider attitudes toward cesarean use?
10. What hospital factors contribute to the use of elective cesarean, e.g. teaching status, geographical region, urban location, socioeconomic status of patients, staffing and scheduling patterns, provider attitudes toward cesarean use?
11. Do audit and feedback interventions influence physician use of cesarean?
12. Do interventions aimed at disrupting staffing and scheduling phenomena—such as the increase in cesarean near change of shifts and differential rates through the week—have promise?
13. Does cesarean use correlate with specific days of the week or time of day?
14. Do different staffing models such as use of hospitalists and integration of midwives reduce the number of cesarean births?
15. Do provider peer-review models change provider patterns of cesarean use?
16. Do natural experiments in tort reform support assertions that liability concerns contribute to use of cesarean?
17. Do natural experiments in payment reform support assertions that certain incentive structures contribute to the use of cesarean?
18. To what degree is use of cesarean driven by uniform compensation for vaginal and cesarean birth as tested by an RCT?
19. Does public reporting of hospital primary and total cesarean rates affect hospital cesarean rates over time?
20. Does public reporting of hospital primary and total cesarean rates affect hospital induction rates over time?
21. Does public reporting of physician primary and total cesarean rates affect physician use of cesarean over time?
22. Does public reporting of physician primary and total cesarean rates affect physician use of induction over time?
23. Does use of informed medical decisionmaking models change patient decisions about desire for cesarean or for procedures such as induction that may increase risk of cesarean?
24. Is the Bishop's score routinely used by providers as a decisionmaking tool? If not, why not?
25. To what extent do patient educational and support tools affect patient decisions to undergo elective cesarean?
26. To what extent do educational tools that manage patient expectations and describe the risks of cesarean influence use of cesarean during labor?
27. Do system level changes applied to all patients in a care setting with the goal of reducing cesarean increase risk of neurodevelopmental delays in children evaluated over years after birth?
28. When strictly operationalized and compared in clinical trials what components of systems intervention are effective in reducing cesarean use?
29. Can technologies to enhance fetal surveillance [specify most promising - are there any technology studies worth doing?] improve infant outcomes while reducing cesarean?
30. Does a protocol for use of scalp pH sampling reduce use of cesarean?
31. Does outpatient hyaluronidase injection into the cervix for cervical ripening at term reduce risk of cesarean (replication of single promising trial)?
32. Does active management of labor, using updated U.S. labor curves, reduce use of cesarean in U.S. community care settings?
33. Does use of the Consortium for Safe Labor labor curves reduce use of cesarean?
34. Does elective induction at 39 weeks vs. expectant management at 39 weeks influence use of cesarean?
35. Can protocols supporting trial of induction of labor make it realistic for physicians to send a patient home if induction of labor does not progress in a timely fashion?
36. What is the mechanism by which doula support exerts an effect?
37. Does midwifery care throughout pregnancy in a hospital setting reduce use of cesarean among low-risk women when compared in a randomized clinical trial to obstetric care?
38. Does midwifery care in labor in a hospital setting reduce use of cesarean among low-risk women when compared in a randomized clinical trial to obstetric care?
39. Can tighter standards for elective induction among primiparous patients reduce use of cesarean?
40. Can tighter standards for indicated induction among primiparous patients reduce use of cesarean?
41. How does implementing uniform definitions for arrest of labor and its management influence use of cesarean?
42. How does implementing a standard indication list affect physicians' use of cesarean?
43. Would changing the definition of when active labor starts reduce use of cesarean?
44. Would changing the timeframes for normal progress in latent and active labor reduce primary cesareans?
45. Would a tighter definition of elective cesarean affect physicians' use of cesarean?
46. What scales/indices best capture factors that mothers and partners value about their birth?
47. As assessed by sociologic models, to what extent are cesarean rates perceived as concerning or not among members of the public, women of childbearing age, obstetrical care providers, payors, and policy makers?
48. What factors have resulted in the change in patterns of the diagnosis of dystocia over the decades?

Table 4 Snowballed list of methodologic recommendations

Methodologic Recommendations
1. Develop data-driven estimates of plausible decreases in cesarean for use in power calculations.
2. Develop definitions of indications for cesarean that can be validated from medical records and case-report forms.
3. Include placebo, sham, or attention control comparison groups, and innovative means of masking patients and providers in studies of interventions.
4. Conduct studies directly comparing and combining candidate strategies to detect additive and multiplicative effects of combining two effective interventions over each effective intervention alone.
5. Design studies with pre-specified secondary outcomes and adequate power for these outcomes.
6. Conduct studies that allow stratification on patient characteristics such as nulliparity and multiparity and have adequate power to detect differences across strata.
7. Track and report total, primary, and repeat cesareans in studies not restricted to nulliparous women.
8. Capture all categories of birth outcomes (cesarean, emergent cesarean, assisted vaginal, and spontaneous vaginal births) and related complications in order to assess if reductions in cesarean occur at the cost of increased use of other interventions or increased complications.
9. Include robust measures of maternal coping, satisfaction, and perceived quality of the birth experience.
10. Expand infant outcomes to include a uniform panel of measures that capture infant status and development better than Apgar scores and NICU admission, including post-discharge measures.
11. Include maternal length of stay and incidence of specific complications such as chorioamnionitis, endometritis, and wound healing complications, as outcomes in studies.
12. Conduct multisite studies to improve applicability and ensure power and precision.
13. Conduct larger trials of health system interventions.
14. Develop registries that capture both long-term and short-term outcomes
15. Determine the best measures of patient and provider route of birth preferences.
16. Consider the relationship between refined definitions of indications for cesarean and existing population based measures (e.g. hospital discharge data) to better identify algorithms that can be used to document indications in both clinical and nonclinical databases.
17. Future studies should include a full range of practice settings including community hospitals, birth centers, and health systems.

Figure 5 Snowballing results

CER = Comparative Effectiveness Review; EPC = Evidence-based Practice Center

Figure 5 is a flowchart that describes the results of the snowballing process. It begins with the EPC's extraction of evidence gap from the comparative evidence review and ends with the stakeholders' completion of a web-based snowballing survey. This figure is described further in the Section entitled “Results” as follows “In Phase 1, the EPC investigators started with the 17 evidence gaps identified in the draft review and translated these gaps into a list of 12 sample research questions and 12 sample methodologic recommendations that have potential utility for reducing cesarean birth. We invited the stakeholder panel to participate in a teleconference and then a web-based survey to make the list broader and more comprehensive and to suggest topics we may have omitted. During the teleconference and snowballing survey, stakeholders expanded the initial list to 47 research questions and 17 methodologic recommendations. These items encompassed a wide range of topics and are presented in Tables 3-4.”

## Prioritization

During initial voting, stakeholders were asked to respond to a Web-based survey in which they distributed 47 points among the research gaps and 17 points among the methodologic issues (Figure 6). Once the surveys were completed, we totaled points for each item, ranked items based on number of points assigned, and eliminated the lowest one-third responses. (Appendix D). The top five research questions were the following:

1. What factors drive a patient's decision to undergo a primary cesarean during labor, e.g. prior cesarean, general fears, fear of future pelvic floor disorders?
2. Why do some patients prefer to undergo elective cesarean?
3. Do different staffing models such as use of hospitalists and integration of midwives reduce the number of cesarean births?
4. What physician factors contribute to the use of cesarean during labor, e.g. residency training, attitude toward cesarean, practice setting, practice size, shift/time of day, use of hospitalists, personal birth experience?
5. Does use of the Consortium for Safe Labor labor curves reduce use of cesarean?

Figure 6 Prioritization results

PiCMe = Prioritization Criteria Method

Figure 6 is a flowchart that describes the results of the prioritization process. It includes 1) results from the initial voting survey (a ranking of 47 research questions and 17 methodologic recommendations and elimination of lowest one-third responses), 2) results from the teleconference (26 research questions and 10 methodologic recommendations), 3) results from the initial ranking survey (16 research questions and 7 methodologic recommendations) and 4) the results of the final ranking (top, middle, and low tier placements for research needs).

The top two methodologic recommendations were:

1. Capture all categories of birth outcomes (cesarean, emergent cesarean, assisted vaginal, and spontaneous vaginal births) and related complications in order to assess if reductions in cesarean occur at the cost of increased use of other interventions or increased complications.
2. Future studies should include a full range of practice settings including community hospitals, birth centers, and health systems.

After the initial voting, we held a second teleconference to discuss results. During the call, stakeholders agreed to eliminate the lowest one-third of items, and combined similar questions to reduce redundancies. This process resulted in a list of 26 research questions and 10 methodologic recommendations.

Next, stakeholders completed an electronic survey and ranked the remaining 26 research questions and ten methodologic improvements from 1 (highest priority) to 26 (lowest priority) and from 1 to 10, respectively. We totaled points for these items, ranked them from fewest points (highest priority) to most points and eliminated the bottom one-third items, leaving 16 research questions and seven methodologic recommendations.

After the initial ranking, the top five research questions were:

1. Can tighter standards for induction (indicated or elective) among primiparous patients reduce use of cesarean?
2. Do different staffing models, e.g. models that use hospitalists or midwives, reduce the number of cesarean births?
3. How does implementing uniform definitions for arrest of labor and its management influence use of cesarean?
4. Would changing the timeframes for normal progress in latent and active labor reduce primary cesareans?
5. What physician factors contribute to the use of cesarean during labor, e.g. residency training, attitude toward cesarean, practice setting, practice size, shift/time of day, use of hospitalists, personal birth experience?

The top two methodologic recommendations were:

1. Capture all categories of birth outcomes (cesarean, emergent cesarean, assisted vaginal, and spontaneous vaginal births) and related complications in order to assess if reductions in cesarean occur at the cost of increased use of other interventions or increased complications.
2. Conduct studies that allow stratification on patient characteristics such as nulliparity and multiparity and have adequate power to detect differences across strata.

## Research Needs

For the final prioritization step, we scored research questions and methodologic recommendations based on total points assigned to seven AHRQ potential value criteria. We established tiers for top-, middle-, and lower-ranked items and created cutoff points where natural breaks in total points assigned occurred. In Tables 5–6, we present research questions and methodologic recommendations by tier. We present the top five research questions and top two methodologic recommendations for each AHRQ criterion in Appendix D, Tables D7–D8.

The top-tier research questions reflect a focus on standardization strategies for induction and arrest of labor (three of five), systems-strategies (one of five) and staffing models (one of five). For strategies that standardize induction and arrest of labor, we recommend cluster randomized controlled trials with randomization of entire labor and delivery units. For trials of systems-level strategies and staffing models, we recommend studies multisite studies to improve power and generalizability.

Table 5 Highest priority research questions

Research Question | Tier | Relevant PICOTS Area(s) | Study Design Comments/Suggestions
When strictly operationalized and compared in clinical trials, what components of systems interventions are effective in reducing cesarean use? | Top | Intervention: promising components of interventions from observational studies Comparator: alternated combinations of components Setting: any U.S. hospital | Multisite efforts likely required for power and to enhance generalizability.
Can tighter standards for induction (indicated or elective) among primiparous patients reduce use of cesarean? | Top | Population: primiparous women Intervention: standards developed by consensus from EBM guidance/reviews Comparator: prior standards | Cluster RCT with randomization at level of whole labor and delivery unit.
How does implementing uniform definitions for arrest of labor and its management influence use of cesarean? | Top | Intervention: standards developed by consensus from EBM guidance/reviews Comparator: usual care | Cluster RCT with randomization at level of whole labor and delivery unit.
Would changing the timeframes for normal progress in latent and active labor reduce primary cesarean? | Top | Intervention: strict implementation of action lines Comparator: usual care Outcome: primary cesarean | Cluster RCT with randomization at level of whole labor and delivery unit.
Do different staffing models, such as models that use hospitalists or midwives, reduce the number of cesarean births? | Top | Intervention: novel staffing model Comparator: conventional staffing model Setting: any U.S. hospitals | Multisite efforts likely required for power and to enhance generalizability.
Does midwifery care throughout pregnancy in a hospital setting reduce use of cesarean among low-risk women when compared in a randomized clinical trial to obstetric care? | Middle | Intervention: continuity of prenatal care and birth with midwives Comparator: continuity of prenatal care and birth with physicians Setting: any U.S. prenatal care/birth setting | Challenges presented by the availability of midwives; however, important to be conducted in the United States and not to infer outcomes from other health systems.
Do natural experiments in payment reform support assertions that certain incentive structures contribute to the use of cesarean? | Middle | Intervention: new models of flat payment for birth regardless of route Comparator: prior payment schedules | Capture existing natural experiments happening around the country by state and by payors' policy changes.
To what extend do educational and decision support tools that describe the risk of cesarean influence use of induction, elective cesarean and cesareans during labor? | Middle | Intervention: distinctive educational and decision support tools for patients Comparator: no use of educational and decision support tools Outcomes: induction, elective and indicated cesarean | Randomized controlled trials and observational studies (especially qualitative) would be appropriate.
What physician factors contribute to the use of cesarean during labor, such as residency training, attitude toward cesarean, practice setting, practice size, shift/time of day, use of hospitalists, personal birth experience? | Middle | Determinants | Qualitative, semi-quantitative, and observational research efforts potentially including use of methods such as focus groups, individual interviews, surveys, predictive models and sociologic analyses.
Does use of the Consortium for Safe Labor labor curves reduce use of cesarean? | Middle | Intervention: determining progress of labor with contemporary U.S. labor curves to define arrest of labor and response Comparator: no formalized use of tracking labor or prior versions of labor curve Setting: any U.S. hospital | These updated labor curves reflect changing U.S. demographics (age, body mass index, parity) and should be compared along with an action plan compared to no formal use of labor curves/usual care. To compare to prior versions will require larger trials.
What factors drive a patient's decision to undergo a primary cesarean during labor, such as prior cesarean, fears, satisfaction with progress of labor, satisfaction with pain management, etc? | Middle | Determinants | Qualitative, semi-quantitative, and observational research efforts potentially including use of methods such as focus groups, individual interviews, surveys, predictive models and sociologic analyses.
Does public reporting affect induction and cesarean rates over time, such as public reporting of total and primary cesarean rates for individual physicians, public reporting of primary and total cesarean rates for hospitals? | Middle | Intervention: distinctive versions of public reporting Outcomes: primary and total cesarean rates Comparator: no public reporting | Could potentially operationalize at county or state level as block randomized trials.
Do audit and feedback interventions influence physician use of cesarean? | Middle | Intervention: audit and feedback with institutional/department awareness of individual data Comparator: usual | Could be paired in 2×2 trials designs with public reporting intervention as above.
To what extent do nonfinancial incentives such as time savings, control and perceived improvement in patient relations affect physician decisions to use cesarean? | Middle | Determinants | Qualitative, semi-quantitative, and observational research efforts potentially including use of methods such as focus groups, individual interviews, surveys, predictive models and sociologic analyses.
What hospital factors contribute to the use of cesarean during labor, such as teaching status, geographical region, urban location, socioeconomic status of patients, staffing and scheduling patterns, provider attitudes toward cesarean use? | Lower | Determinants | National database efforts that expand on prior risk adjustment models and seek additional explanatory variables would have value for understanding contemporary drivers of cesarean use.

Table 6 Highest priority methodologic recommendations

Methodologic Recommendation | Tier | Relevant PICOTS Area(s) | Study Design Comments/Suggestions
Capture all categories of birth outcomes (primary and repeat cesarean, emergent cesarean, assisted vaginal, and spontaneous vaginal births) and related complications and stratify outcomes by parity. | Top | Outcomes (operationalize outcome definitions for each category of birth, maternal and neonatal outcomes for consistency across literature) | Unified definitions with validation studies to determine if operational definitions are uniformly applied are crucial to being able to compare findings in this literature and to aggregate results for efforts such as meta-analysis.
Develop registries that capture both short-term and long-term outcomes. | Top | Outcomes (uniform birth, maternal, and infant outcomes needed as above) | Incorporating uniform operational definitions within a registry would allow for the first time ability to refine knowledge about determinants of cesarean from a national sample of varied settings and populations.
Future studies should include a full range of practice settings including community hospitals and birth centers. | Middle | Setting: all birth settings in the United States | Research needs to be extended past academic/tertiary care sites in order to reflect the settings in which women receive birth care.
Expand infant outcomes to include a uniform panel of measures that capture infant status and development better than Apgar scores and NICU admission, including post-discharge measures. | Middle | Outcomes (these are needed to understand potential adverse consequences for infants) | Diverse settings and uniform definitions would be required. Should become part of registry efforts.
Develop definitions of indications for cesarean that can be validated from medical records and case-report forms. | Middle | Intervention (operationalize definitions of indications to make them discrete, nonoverlapping categories) | Unified definitions with validation studies to determine if operational definitions are uniformly applied are crucial to being able to compare findings in this literature and to aggregate results for efforts such as meta-analysis.
Include maternal length of stay and incidence of specific complications such as chorioamnionitis, endometritis, and wound healing complications, as outcomes in studies. | Lower | Outcomes (these are needed to understand potential adverse consequences for mothers) | Diverse settings and uniform definitions would be required. Should become part of registry efforts.
Determine the best measures of patient and provider route of birth preferences. | Lower | Outcomes (development of measurement tools is necessary) | We need greater understanding from diverse populations of women and providers about how they interpret the relative value of outcomes and gauge satisfaction with the birth experience.

## Identification of Current and Ongoing Studies

Few studies explicitly set out to reduce cesarean births. We identified six ongoing randomized controlled trials using the search criteria from the original review. The RCTs addressed pregnancy/fetal monitoring (1), prolonged pregnancy (1), maternal obesity/weight gain (3), and labor dystocia (1). The RCTs that address fetal monitoring and labor dystocia may address the research needs we identified in this project.