# References

1 Menacker F, Hamilton BE. Recent trends in cesarean delivery in the United States. NCHS Data Brief. Mar. 2010;(35):1-8. [pmid: 20334736].
2 Martin JA, Hamilton BE, Sutton PD, et al. Births: final data for 2007. Natl Vital Stat Rep. Aug. 9. 2010;58(24):1-85. [pmid: 21254725].
3 Bettes BA, Coleman VH, Zinberg S, et al. Cesarean delivery on maternal request: obstetrician-gynecologists' knowledge, perception, and practice patterns. Obstet Gynecol. Jan. 2007;109(1):57-66. [pmid: 17197588].
4 Simpson KR, Thorman KE. Obstetric “conveniences”: elective induction of labor, cesarean birth on demand, and other potentially unnecessary interventions. J Perinat Neonatal Nurs. Apr-Jun. 2005;19(2):134-44. [pmid: 15923963].
5 Prioritization criteria methodology for future research needs proposals within the Effective Health Care Program. Rockville, MD. Agency for Healthcare Research and Quality. 2012.
6 Zhang J, Troendle J, Reddy UM, et al. Contemporary cesarean delivery practice in the United States. Am J Obstet Gynecol. Oct. 2010;203(4):326 e1-e10. [pmid: 20708166].
7 The Joint Commission. Specifications manual for Joint Commission national quality core measures. 2010. http://manual.jointcommission.org/releases/TJC2010B/MIF01067.html. February 4 2011.
8 National Institutes of Health Consensus Development conference statement: vaginal birth after cesarean: new insights March 8-10, 2010. Obstet Gynecol. Jun. 2010;115(6):1279-95. [pmid: 20502301].
9 NIH consensus development statement on cesarean childbirth. The Cesarean Birth Task Force. Obstet Gynecol. Apr. 1981;57(4):537-45. [pmid: 7243111].
10 Getahun D, Oyelese Y, Salihu HM, et al. Previous cesarean delivery and risks of placenta previa and placental abruption. Obstet Gynecol. Apr. 2006;107(4):771-8. [pmid: 16582111].
11 Blanchette H. The rising cesarean delivery rate in America: what are the consequences?. Obstet Gynecol. Sep. 2011;118(3):687-90. [pmid: 21860302].
12 Clark SL, Belfort MA, Hankins GD, et al. Variation in the rates of operative delivery in the United States. Am J Obstet Gynecol. Jun. 2007;196(6):526 e1-5. [pmid: 17547880].
13 Wennberg J. Which rate is right?. N Engl J Med. Jan. 30. 1986;314(5):310-1. [pmid: 3941721].
14 Wennberg JE. Tracking Medicine: A Researcher's Quest to Understand Health Care. Oxford, England. Oxford University Press. 2010.
15 Baicker K, Buckles KS, Chandra A. Geographic variation in the appropriate use of cesarean delivery. Health Aff (Millwood). Sep-Oct. 2006;25(5):w355-67. [pmid: 16895942].
16 Luthy DA, Malmgren JA, Zingheim RW, et al. Physician contribution to a cesarean delivery risk model. Am J Obstet Gynecol. Jun. 2003;188(6):1579-85. discussion 85-7. [pmid: 12824996].
17 National Center for Health Statistics. Healthy People 2000 Final Review. Hyattsville, MD. Public Health Service. 2001.
18 U.S. Department of Health and Human Services. Healthy People 2010: Understanding and Improving Health. Washington, DC. U.S. Government Printing Office. 2000. http://www.healthypeople.gov/2010. May 5 2011.
19 U.S. Department of Health and Human Services. Healthy People 2020. Washington, DC. 2011. http://www.healthypeople.gov/2020/default.aspx. May 5 2011.
20 Cyr RM. Myth of the ideal cesarean section rate: commentary and historic perspective. Am J Obstet Gynecol. Apr. 2006;194(4):932-6. [pmid: 16580278].
21 Resnik R. Can a 29% cesarean delivery rate possibly be justified?. Obstet Gynecol. Apr. 2006;107(4):752-4. [pmid: 16582108].
22 Gruber J, Kim J, Mayzlin D. Physician fees and procedure intensity: the case of cesarean delivery. J Health Econ. Aug. 1999;18(4):473-90. [pmid: 10539618].
23 Zwecker P, Azoulay L, Abenhaim HA. Effect of fear of litigation on obstetric care: a nationwide analysis on obstetric practice. Am J Perinatol. Apr. 2011;28(4):277-84. [pmid: 21249618].
24 Dursun P, Yanik FB, Zeyneloglu HB, et al. Why women request cesarean section without medical indication?. J Matern Fetal Neonatal Med. Sep. 2011;24(9):1133-7. [pmid: 21668323].
25 Quiroz LH, Blomquist JL, Macmillan D, et al. Maternal goals for childbirth associated with planned vaginal and planned cesarean birth. Am J Perinatol. Oct. 2011;28(9):695-702. [pmid: 21660899].
26 O'Boyle AL, Davis GD, Calhoun BC. Informed consent and birth: protecting the pelvic floor and ourselves. Am J Obstet Gynecol. Oct. 2002;187(4):981-3. [pmid: 12388991].
27 Handa VL, Blomquist JL, Knoepp LR, et al. Pelvic floor disorders 5-10 years after vaginal or cesarean childbirth. Obstet Gynecol. Oct. 2011;118(4):777-84. [pmid: 21897313].
28 Bayrampour H, Heaman M. Advanced maternal age and the risk of cesarean birth: a systematic review. Birth. Sep. 2010;37(3):219-26. [pmid: 20887538].
29 Kulie T, Slattengren A, Redmer J, et al. Obesity and women's health: an evidence-based review. J Am Board Fam Med. Jan-Feb. 2011;24(1):75-85. [pmid: 21209347].
30 Khunpradit S, Tavender E, Lumbiganon P, et al. Non-clinical interventions for reducing unnecessary caesarean section. Cochrane Database Syst Rev. 2011;(6):CD005528. [pmid: 21678348].
31 Catling-Paull C, Johnston R, Ryan C, et al. Non-clinical interventions that increase the uptake and success of vaginal birth after caesarean section: a systematic review. J Adv Nurs. Aug. 2011;67(8):1662-76. [pmid: 21535091].