# Methods

Our protocol for obtaining stakeholder input on research question prioritization was loosely based on the principles of the Delphi process, modified to maximize response and facilitate stakeholder discussions. In short, we began by identifying a list of candidate research topics and initiating an iterative electronic process to refine and then rank the topic list. We also conducted two teleconferences that allowed personal interaction between the participants and discussion of the research priorities.

The protocol for this project was reviewed and approved by the Vanderbilt Institutional Review Board. Potential stakeholders were contacted by email, with a followup personal phone call as needed, to participate in the process.

The three phases of this project were (1) identification of evidence gaps, (2) stakeholder engagement and prioritization of future research needs, and (3) recommendations for optimal study design. This section summarizes these phases.

## Identification of Evidence Gaps

In the draft CER, we identified research gaps for strategies to reduce cesarean birth for low-risk women. We then developed a list of sample research questions and methodologic recommendations, based on the draft review and input from our EPC content experts. We invited the stakeholder panel to participate in a teleconference and then a web-based survey to make the list broader and more comprehensive and to suggest topics we may have omitted. We intentionally did not ask the stakeholders to rank questions or to suggest ways to reduce the number of items at this snowballing point in the process, as we wanted to be as inclusive as possible, to ensure that the review panel would have a complete and relatively unbiased list of research topics from which to begin the prioritization process. Figure 2 illustrates the process.

Figure 2 Identification of evidence gaps

CER = Comparative Effectiveness Review; EPC = Evidence-based Practice Center

Figure 2 is a flowchart that outlines the evidence gap identification process. It includes 1) the EPC's extraction of evidence gap from the comparative evidence review, 2) the EPC's expansion of the list into a list of sample researchable questions and methodologic recommendations and 3) the stakeholders' expansion (“snowballing”) of the list of sample items. This figure is described further in the Section entitled “Methods” as follows: “in the draft CER, we identified research gaps for strategies to reduce cesarean birth for low-risk women. We then developed a list of sample research questions and methodologic recommendations, based on the draft review and input from our EPC content experts. We invited the stakeholder panel to participate in a teleconference and then a web-based survey to make the list broader and more comprehensive and to suggest topics we may have omitted. We intentionally did not ask the stakeholders to rank questions or to suggest ways to reduce the number of items at this snowballing point in the process, as we wanted to be as inclusive as possible, to ensure that the review panel would have a complete and relatively unbiased list of research topics from which to begin the prioritization process.”

We developed a list of ongoing research and funding opportunities to help determine if research needs were currently being addressed and the general direction of current research.

To identify currently funded or recently completed randomized trials intended to reduce use of cesarean birth (Appendix C), we conducted searches of U.S. government resources (i.e. ClinicalTrials.gov, NIH Reporter), international trial registries (e.g. Current Controlled Trials), and other potential funding sources such as relevant associations and organizations (e.g. American College of Nurse-Midwives, American Congress of Obstetricians and Gynecologists). Our searches were broad, employing the use of the keywords “cesarean” and “caesarean” with an accompanying scan of retrieved projects to identify those using a randomized trial design. We assessed the list against the CER inclusion criteria and shared the list with stakeholders at the beginning of the snowballing process.

## Criteria for Prioritization

Our protocol for prioritization included three iterative steps: initial voting, initial ranking, and final ranking of reduced list of items.

### Initial Voting

We initiated prioritization with the snowballed list of items which included 47 research questions and 17 methodologic recommendations. Stakeholders were asked to respond to a web-based survey in which they distributed 47 points among the research gaps and 17 points among the methodologic issues. Items with the most points were considered the most popular. At the conclusion of this step the items with the lowest one-third of responses were eliminated. During a teleconference we asked stakeholders to examine the remaining questions for possible ways to reduce redundancies across questions and combine questions that could be answered in one study design

### Initial Ranking

Stakeholders then ranked the remaining 26 research questions and 10 methodologic improvements from 1 to 26 and 1 to 10, respectively. The research questions and methodologic improvements that were ranked the lowest one-third were eliminated.

### Final Ranking of Reduced List of Items

We then sent the reduced list of 16 future research questions and seven methodologic issues to the stakeholders and asked them to again rank items across the seven criteria from the AHRQ Prioritization Criteria Method (PiCMe). The seven criteria included:

- Potential for significant health impact
- Potential to reduce variation in clinical practices
- Potential for significant economic impact
- Potential risk from inaction
- Potential to address inequities
- Potential to allow assessment of ethical, legal, and social issues pertaining to the condition, and
- Potential for new knowledge

Responses to this final prioritization exercise were then used to create a ranked list of the topics. For this final prioritization step, we scored research questions and methodologic recommendations based on total points assigned to seven AHRQ criteria. We established tiers for top-, middle-, and lower-ranked items and created cut-off points where natural breaks in total points occurred. This tiered list represents our final list of research needs and recommendations. To provide more detail about top-tier items for each specific AHRQ criterion, we identified the top-five research questions and top-two methodologic recommendations for each criterion. Figure 3 describes the prioritization process.

Figure 3 Prioritization process

PiCMe = Prioritization Criteria Method

Figure 3 is a flowchart that outlines the research need prioritization process. It includes 1) an initial voting survey, 2) a teleconference, 3) an initial ranking survey and 4) a final ranking survey. This figure is described further in the Section entitled “Methods” as follows: “Our protocol for prioritization included three iterative steps: initial voting, initial ranking, and final ranking of reduced list of items. We initiated prioritization with the snowballed list of items which included 47 research questions and 17 methodologic recommendations. Stakeholders were asked to respond to a web-based survey in which they distributed 47 points among the research gaps and 17 points among the methodologic issues. Items with the most points were considered the most popular. At the conclusion of this step the items with the lowest one-third of responses were eliminated. During a teleconference we asked stakeholders to examine the remaining questions for possible ways to reduce redundancies across questions and combine questions that could be answered in one study design. Stakeholders then ranked the remaining 26 research questions and 10 methodologic improvements from 1-26 and 1-10, respectively. The research questions and methodologic improvements that were ranked the lowest one-third were eliminated. We then sent the reduced list of 16 future research questions and seven methodologic issues to the stakeholders and asked them to again rank items across the seven criteria from the AHRQ Prioritization Criteria Method (PiCMe). The seven criteria included: •Potential for significant health impact •Potential to reduce variation in clinical practices •Potential for significant economic impact •Potential risk from inaction •Potential to address inequities •Potential to allow assessment of ethical, legal, and social issues pertaining to the condition, and •Potential for new knowledge. Responses to this final prioritization exercise were then used to create a ranked list of the topics. For this final prioritization step, we scored research questions and methodologic recommendations based on total points assigned to seven AHRQ criteria. We established tiers for top-, middle-, and lower-ranked items and created cut-off points where natural breaks in total points occurred. This tiered list represents our final list of research needs and recommendations. To provide more detail about top-tier items for each specific AHRQ criterion, we identified the top-five research questions and top-two methodologic recommendations for each criterion.”

## Engagement of Stakeholders, Researchers, and Funders

The Vanderbilt EPC investigators worked to develop a group of stakeholder individuals and organizations with expertise and vested interest in the topic. We aimed for balanced representation in the following areas: clinical practice, advocacy, research, and research funding

The EPC investigators developed an initial list of stakeholder individuals and organizations using (1) the CER Technical Expert Panel (TEP) list and (2) recommendations from the EPC, (3) authors in the related literature, and (4) advocates in the area of informed medical decision-making. The TEP list served as a logical starting place because TEP members are experts in the area of strategies to reduce cesarean birth, are knowledgeable about research and funding developments, and were familiar with the scope and findings from the CER. The EPC identified and invited candidate stakeholders based on likely availability, expertise, and ability to offer multiple perspectives (e.g. clinical and advocacy). EPC investigators recommended additional individuals and organizations not included in the original TEP list that represented stakeholder “types” identified in the project protocol (researchers, clinicians, and service providers; funding agency representatives; health care policymakers; representatives from professional societies/organizations; and patient advocacy groups).

Twenty-four invitations to participate were emailed to identified experts and/or stakeholder organizations (Appendix A). Reminder emails were sent as needed. The invitation included an overview of the project, what participation would entail, and contact information should they have any questions. The invitation informed stakeholders that participation was voluntary and described our efforts to maintain confidentiality and the risks and benefits of participation.

Many stakeholders represented multiple perspectives, e.g. clinician/researcher/advocate. We anticipated that no more than nine non-Federal stakeholders would participate in each step of research gap identification and prioritization. We obtained the standard AHRQ Conflict of Interest forms from all participants including our EPC faculty and staff. None of the identified stakeholders or EPC team members had a conflict judged to preclude participation in the process.

In order to increase stakeholder understanding of the purpose of the project, key steps, and how we would be soliciting their input over time, and to allow personal interaction among stakeholders, we conducted a teleconference. The teleconference also served as the starting point for stakeholder snowballing. Twelve out of 13 stakeholders participated in this teleconference. Prior to the call, we emailed each stakeholder the draft CER, slides describing the evidence gap identification and prioritization processes, a project timeline, and a list of sample research questions and methodologic recommendations. We spent a short amount of time—less than 15 minutes—with the project overview and reserved the majority of time for discussion of research needs.

With the permission of the stakeholders, we recorded and transcribed the teleconference. During the call, there was a fair amount of discussion about patient, physician, nurse, and hospital factors that influence cesarean use. As one stakeholder commented, “peripheral issues become important.” There was some disagreement about whether there is sufficient evidence that specific factors (e.g. organizational culture, professional training, fear of pelvic floor disorders) influence patient and provider perceptions and decisions about cesarean birth. Other items that emerged during the snowballing process were tighter standards for induction and elective cesarean; uniform definitions for arrest of labor; the role of incentives (financial and nonfinancial); and effects of using updated labor curves, peer review systems, audit and feedback, public reporting, novel staffing and scheduling models, and systems-level strategies.

At the end of the teleconference, we summarized next steps, which included completing the snowballing process online, completing two prioritization surveys online, and participating in a second teleconference. After the call, we emailed a link for the snowballing survey and made it available for comment from March 21 to April 3, 2012. The survey asked stakeholders to add new questions and recommendations if they saw gaps in these lists and to provide feedback on the listed research questions and recommendations. Through the teleconference and online survey, the “snowballing process” yielded a total of 47 research questions and 17 recommendations.

During the prioritization process, stakeholders were able to provide input through three web-based surveys and a teleconference. The first survey (multivoting survey) asked stakeholders to distribute 47 points among the research gaps and 17 points among the methodologic recommendations. This survey was open from April 24 to May 8, 2012. When all surveys were returned, we totaled the number of points each item received, ranked items in order from most to least points, and eliminated the lowest one-third of the items. We conducted a teleconference to reduce redundancy in questions and build consensus on the current list of items. Stakeholders participated in two additional rounds of prioritization (See Criteria for Prioritization).

Responses to this final prioritization exercise were then used to create a ranked list of the topics. For this prioritization, research questions and methodologic recommendations were scored using both a combined score across each of the seven domains and by domain.

During the snowballing and ranking process the participant stakeholders had no information about the identities of the other participants. Until the conclusion of each step they did not have access to scores and then only to the aggregate. Beginning the process with recruitment of additional items was intended to allow the scope of topics for future research to expand and to ensure that a large number and range of potentially important topics were considered. Because the group did their work electronically, individual persuasiveness or dominance of the conversation by particular topics did not have potential to sway the group opinion or the overall process.

## Research Question Development and Research Design Considerations

We did not have stakeholders rank study designs or provide input to proposed study designs, due to the length and complexity of this process as well as the wide range of stakeholder technical experience in this area. EPC investigators developed suggestions and considerations for optimal study designs.

The final list of highest priority research needs and recommended study designs will be presented to the stakeholders when the draft report is posted for public comment.