# Addendum

This report was posted for public comment on the AHRQ Effective Health Care Web site from October 22, 2012, to November 19, 2012. A commenter noted that family medicine practitioners are important stakeholders to engage in research related to maternity care as they often provide care to pregnant women. The Comparative Effectiveness Review (CER) Key Informant group and Technical Expert Panel included two individuals representing family medicine. These representatives provided input and guidance as we developed the CER, including the CER section on future research needs, which served as the springboard for the Future Research Needs (FRN) prioritization project. Family medicine representatives also peer reviewed the full CER. In addition, the FRN stakeholder workgroup included a representative from family medicine. We did attempt, albeit unsuccessfully, to include additional family medicine representatives as part of the FRN stakeholder group. We agree that inclusion of family medicine practitioners as stakeholders is important; however, as this comment did not materially affect the content of the report, we did not make any changes.

A commenter also noted that further research in this area is not necessary; rather, the health care community should act on current knowledge about promoting vaginal births. We agree that the health care community should continue the use of evidence-based practices to reduce cesarean births. However, the CER identified a number of evidence gaps and methodologic challenges that can be and should be addressed by future studies. For the majority of strategies included in the CER, the evidence is insufficient, including many instances in which a single study is the only evidence supporting the approach. The top-tier research questions identified in the FRN report encompass strategies for which strength of evidence is insufficient to low due to few quality studies. Additional quality trials are needed to confirm the effectiveness of strategies and address methodologic limitations found in the current literature. As this comment did not materially affect the content of the report, we did not make any changes.