# Executive Summary

## Background

This investigation of future research needs builds on the Comparative Effectiveness Review (CER) Strategies To Reduce Cesarean Birth in Low-Risk Women, conducted by the Vanderbilt Evidence-based Practice Center (EPC). The rationale for the review is a concerning increase in cesarean use over the past decade. Thirty-two percent of pregnancies in the United States conclude with a cesarean birth.1 This record high rate reflects a relative increase of 53 percent in use of cesarean from 1991 to 2007.^1^ The pattern of increasing use of cesarean has been of concern for decades, with the last decline of 2 to 3 percent, occurring in the mid-1990s, being fully reversed by 1999, and the rate increasing more than 50 percent from 1996 to 2007.^2^ Nearly one in three births by cesarean translates to a total of 1.4 million cesarean births each year, making cesarean the most commonly performed major surgery in the United States.1

Research has addressed predictors of cesarean such as the shift toward older maternal age, higher body mass index, greater maternal comorbidity, use of assisted reproductive technology, and increased incidence of multiple gestations.3,4 Nonetheless, relatively little focus has been placed on research specifically designed to assess strategies to reduce use of cesarean. The CER aimed to bring that literature to the forefront by systematically examining the outcomes of interventions intended to reduce use of cesarean among low-risk women.

The Comparative Effectiveness Review addressed the following Key Questions (KQs):

- KQ1. What strategies during pregnancy are effective to reduce the use of cesarean birth among women with a singleton pregnancy who are intending a vaginal birth?
- KQ2. What strategies during labor are effective to reduce the use of cesarean birth among women with a singleton pregnancy who are intending a vaginal birth?
- KQ3. Where head-to-head comparisons are available, what strategies are shown to be superior in reducing the use of cesarean birth among women with a singleton pregnancy who are intending a vaginal birth?
- KQ4. What are the nature and frequency of adverse effects resulting from strategies used to reduce cesarean birth among women with a singleton pregnancy who are intending a vaginal birth?

After reviewing the evidence, the EPC investigators concluded that, while some strategies show promise, no particular strategy was uniformly successful in reducing cesareans. The strength of the evidence was low to insufficient for each of the strategies reviewed.

The CER noted topic-related evidence gaps in the literature and common methodologic issues. These gaps are summarized in Tables A and B, and categorized by the most relevant PICOTS (population, intervention, comparator, outcome, timing, and setting) elements. Two of the eight topic-related evidence gaps do not fit within the PICOTS framework and are described as “determinants.” These gaps relate to macrolevel factors that influence patient, provider, and system preferences about cesarean and decisions to use cesarean. Similarly, two of the nine methodologic issues apply generally to studies and not to a specific PICOTS element. These issues are described as “cross-cutting.”

Table A Evidence gaps identified in the Comparative Effectiveness Review

Evidence Gap | Relevant PICOTS Elements
Gaps in knowledge about the determinants of cesarean use, including patient, sociocultural, and health care system characteristics | Determinants Timing Setting
Need for qualitative and quantitative research to help determine what factors are contributing to decisions to have elective cesarean | Determinants Timing Setting
Need for multisite research and research across the different racial/ethnic and socioeconomic groups representative of the U.S. population | Population Timing Setting
Need for randomized trials at the systems level to ascertain whether promising intervention components are indeed effective in promoting decreased use of cesarean | Intervention Timing Setting
Need for understanding of the mechanism by which interventions such as doula support exert an effect | Intervention Timing Setting
Gaps in understanding of the effects of staffing models and health care technologies on cesarean rates | Intervention Timing Setting
Need for understanding of the role of informed medical decisionmaking | Intervention Timing Setting
Need for understanding of the role of tort reform and subsequent litigation in cesarean trends | Intervention Timing Setting

Note: PICOTS = population, intervention, comparator, outcome, timing, and setting; they refer to the framework used by the Effective Health Care Program to summarize study characteristics.

Table B Methodologic issues identified in the Comparative Effectiveness Review

Methodologic Issue | Relevant PICOTS Element
Lack of appropriately powered randomized trials | Cross-cutting
Lack of power calculations based on plausible estimates | Cross-cutting
Need for validated consensus definitions of indications for cesarean | Intervention
Need for placebo, sham, or attention control comparison groups | Comparators
Need for replications and comparisons of promising interventions | Comparators
Need for tracking and reporting of total, primary, and repeat cesareans in studies not restricted to nulliparous women | Outcomes
Lack of secondary outcomes specified a priori | Outcomes
Need for expanded maternal and infant outcomes and measures of maternal coping, satisfaction, and perceived quality of the birth experience | Outcomes
Need for long-term followup of infants | Outcomes

Note: PICOTS = population, intervention, comparator, outcome, timing, and setting; they refer to the framework used by the Effective Health Care Program to summarize study characteristics.

Figure A presents the analytic framework for the CER, which has been modified here to illustrate research gaps identified in the report.

Figure A Analytic framework for strategies to reduce cesarean birth in low-risk women

NICU = neonatal intensive care unit; RCT = randomized controlled trial

Note: Numbers in circles represent the position of Key Questions in the intervention process.

Figure A is an analytic framework that summarizes strategies to reduce cesarean birth in low-risk women before and/or during labor, intermediate outcomes such as labor progression, maternal coping, and pain management, and long-term outcomes such as route of birth, maternal morbidity and mortality, or neonatal morbidity. The framework illustrates research gaps identified in the continuing effectiveness review.

## Methods

Our protocol for obtaining stakeholder input on research question prioritization was loosely based on the principles of the Delphi process, modified to maximize response and facilitate stakeholder discussions. The three phases of this project were (1) identification of evidence gaps, (2) stakeholder engagement and prioritization of future research needs, and (3) recommendations for optimal study design.

We invited 24 stakeholders with interests and expertise relevant to reducing use of cesarean. We aimed for balanced representation in the following areas: clinical practice, advocacy, research, and research funding. In phase 1, the EPC investigators developed a list of sample research questions and recommendations for methodologic improvements, based on gaps identified in the draft review of the CER and input from our EPC content experts. We invited the stakeholder panel to participate in a teleconference and then a Web-based survey to make the list broader and more comprehensive, and to suggest topics we may have omitted. We intentionally did not ask the stakeholders to rank questions or to suggest ways to reduce the number of items at this “snowballing” stage of the process, as we wanted to be as inclusive as possible to ensure that the review panel would have a complete and relatively unbiased list of research topics from which to begin the prioritization process.

In phase 2, stakeholders completed three rounds of a modified Delphi process to prioritize research needs. Stakeholders completed a multivoting survey in which they distributed 47 points among the research gaps and 17 points among the methodologic improvements. At the conclusion of this step, the items with the lowest one-third of responses were eliminated. During a teleconference, we asked stakeholders to examine the remaining questions for possible ways to reduce redundancies across questions and combine questions that could be answered in one study design. Next, stakeholders completed a ranking survey in which they ranked the remaining 26 research questions and 10 methodologic improvements from 1 to 26 (highest to lowest) and 1 to 10, respectively. The research questions and methodologic improvements that were ranked in the lowest one-third were eliminated. The last step of the modified Delphi process was the final ranking. Stakeholders ranked the remaining items across the seven domains from the Prioritization Criteria Method (PiCMe).5 Responses to this final prioritization exercise were then used to create a ranked list of the topics. Items were ranked based on total points assigned to the following seven AHRQ criteria and placed in a top-, middle-, or low-tier category.

- Potential for significant health impact
- Potential to reduce variation in clinical practices
- Potential for significant economic impact
- Potential risk from inaction
- Potential to address inequities
- Potential to allow assessment of ethical, legal, and social issues pertaining to the condition
- Potential for new knowledge

In phase 3, EPC investigators developed recommendations for optimal study designs for the remaining research questions.

## Results

Of the 24 stakeholders invited, 13 agreed to participate. Members of the stakeholder group represented clinical practice, maternal health research, health policy, and patient advocacy. The group included five Key Informants/Technical Expert Panel members from the CER. Stakeholder participation is summarized in Figure B.

Figure B Stakeholder participation at each phase of the prioritization process

Figure B is a flowchart that outlines the results of stakeholder recruitment and levels of stakeholder participation throughout the prioritization phase of the project. It begins with the total number of individuals invited to participate in the project (24 stakeholders) and ends with the number and percentage of stakeholders who completed the final round of prioritization (9, 69%). The figure is described further in the Section entitled “Results” as follows: “A total of 13 stakeholders (2 federal, 11 nonfederal) representing the perspective of patient advocacy groups, academic researchers, obstetricians and gynecologists, nursing and nurse-midwifery professional organizations, the payor perspective, and national foundations and societies agreed to participate in one or more of the stages of ranking and prioritization. The group includes five Key Informants/Technical Expert Panel members from the draft CER. Throughout the teleconferences and surveys, stakeholder participation varied from 69% to 84%.”

In phase 1, the EPC investigators developed a list of 12 sample research questions and 12 sample methodologic improvements based on evidence gaps identified in the draft review of the CER. This list served as the nidus for stakeholder snowballing. We invited the stakeholder panel to participate in a teleconference and then a Web-based survey to make the list broader and more comprehensive, and to suggest topics we may have omitted. During the snowballing process, stakeholders expanded the initial list to 47 research questions and 17 methodologic recommendations.

In phase 2, stakeholders completed three rounds of a modified Delphi process to identify and prioritize research needs. The final round of prioritization resulted in a list of 16 research questions and 7 recommendations for methodologic improvements ranked by total points assigned to all 7 AHRQ criteria. Tables C and D present the top-tier future research questions and methodologic recommendations.

Table C Top-tier research questions from final prioritization

Research Question
When strictly operationalized and compared in clinical trials, what components of systems interventions are effective in reducing cesarean use?
Can tighter standards for induction (indicated or elective) among primiparous patients reduce use of cesarean?
How does implementing uniform definitions for arrest of labor and its management influence use of cesarean?
Would changing the timeframes for normal progress in latent and active labor reduce primary cesarean?
Do different staffing models, such as models that use hospitalists or midwives, reduce the number of cesarean births?

Table D Top-tier methodologic recommendations from final prioritization

Methodologic Recommendation
Capture all categories of birth outcomes (primary and repeat cesarean, emergent cesarean, assisted vaginal, and spontaneous vaginal births) and related complications, and stratify outcomes by parity.
Develop registries that capture both short-term and long-term outcomes.

## Discussion

This project resulted in a list of top-priority research needs that encompass a variety of topics, including standardization strategies for induction and arrest of labor, systems-level strategies, and novel staffing models. The top-tier methodologic recommendations highlight the importance of capturing both short- and long-term birth outcomes.

Inherent challenges face investigators and funding agencies that wish to better understand approaches to reduce use of cesarean among low-risk women. Recent reports by the Consortium on Safe Labor, a group of 19 U.S. hospitals conducting an observational study on labor progression and the use and timing of cesareans among women with labor protraction and arrest, show that cesarean birth among women having their first birth has risen to almost one in three.6 Much of this increase occurred in the past decade.1 In the current cultural milieu, it cannot be taken for granted that all those who participate in decisions about births and in providing care for women during pregnancy and birth share an objective of reducing use of cesarean.

To obtain meaningful answers that are applicable to the care of women in the United States will require large-scale studies in this country. Several factors suggest that this research will need to be predominantly conducted as multisite randomized trials: (1) existing wide variability in use of cesarean means different settings will enter with a different baseline propensity to use cesarean; (2) baseline use patterns are only part of the culture of care at an institution and desire to change use of cesarean likely varies, so interventions need to be shown to be effective across settings; and (3) secular trends in cesarean use not related to the intervention being studied impair the ability of observational studies to definitively provide evidence for effectiveness. Some topics, such as investigation of comprehensive midwifery care to reduce cesarean use, will challenge the ability of the care system to identify sufficient numbers of providers across multiple sites who are able and willing to participate in such studies. Furthermore, as the methodologic recommendations of this report suggest, a substantial amount of consensus work needs to be done among researchers, professional organizations, and funders to ensure that the metrics used in research produce data that can be synthesized across families of studies to reach sufficient strength of evidence to inform decisions about care around the Nation.

The priorities identified in this project suggest the importance of research at all points along the continuum represented by our analytic framework. Multiple points of influence need to be studied and the gaps are substantial. The efforts of the stakeholders and our team have identified a multidecade portfolio of questions that need answers.

The high-priority research needs identified in this project inform various points along our analytic framework and the research spectrum—from understanding determinants of cesarean to creating uniform standards and practices for induction and cesarean, exploratory studies, large trials in multiple settings for specific strategies, and creating uniform and expanded panels of outcomes to improve data collection efforts.

## Conclusion

Our multistep process for identifying, multiplying, and prioritizing research questions to advance research in the area of strategies to reduce cesarean birth in low-risk women resulted in an actionable list of research topics to fill specific knowledge gaps. The highest priority research questions encompass many topics of interest, which reflect the large number of gaps in the literature. These topics include study of the influence of tighter standards and definitions for induction and cesarean use (elective and indicated); new measures for labor progress; and trials that test the effectiveness of systems-level strategies, midwifery care, payment reform, and novel staffing models for birth units. Randomized controlled trials, multisite studies that improve power and generalizability, and natural experiments were viewed as critical. The highest priority methodologic recommendations call for uniform use of consensus definitions and tracking of short- and long-term maternal and neonatal outcomes.

## References

1 Menacker F, Hamilton BE. Recent trends in cesarean delivery in the United States. NCHS Data Brief. Mar. 2010;(35):1-8. [pmid: 20334736].
2 Martin JA, Hamilton BE, Sutton PD, et al. Births: final data for 2007. Natl Vital Stat Rep. Aug. 9. 2010;58(24):1-85. [pmid: 21254725].
3 Bettes BA, Coleman VH, Zinberg S, et al. Cesarean delivery on maternal request: obstetrician-gynecologists' knowledge, perception, and practice patterns. Obstet Gynecol. Jan. 2007;109(1):57-66. [pmid: 17197588].
4 Simpson KR, Thorman KE. Obstetric “conveniences”: elective induction of labor, cesarean birth on demand, and other potentially unnecessary interventions. J Perinat Neonatal Nurs. Apr-Jun. 2005;19(2):134-44. [pmid: 15923963].
5 Prioritization criteria methodology for future research needs proposals within the Effective Health Care Program [Draft document]. Rockville, MD. Agency for Healthcare Research and Quality. 2012.
6 Zhang J, Troendle J, Reddy UM, et al. Contemporary cesarean delivery practice in the United States. Am J Obstet Gynecol. Oct. 2010;203(4):326 e1-e10. [pmid: 20708166].