# Discussion

The purpose of this project was to generate a list of high-priority future research needs for strategies to reduce cesarean birth by soliciting stakeholder input through a multistep consensus building process. In the first phase of this process, stakeholders used a two-step snowballing process to expand an initial list of research questions and methodologic recommendations. In the second phase, we engaged stakeholders in a series of prioritization steps that resulted in a gradual reduction of listed items. In the final round of prioritization, stakeholders ranked the remaining 16 research questions and 10 methodologic recommendations across 7 AHRQ potential value criteria. These ranked items were assigned to top-, middle- and lower-priority tiers.

Since the 1980s researchers and policymakers have sought to implement strategies both in the context of trials and systems level changes to reduce the number of cesarean births in low-risk women. The CER concluded that while some strategies show promise, no particular strategy was uniformly successful in reducing cesareans. The strength of the evidence was low to insufficient for each of the strategies reviewed. While certain components of systems-level strategies were common among successful strategies, none were supported by a randomized trial.

Two changes are recommended for future stakeholder engagement processes. First, allow ample time—at least a month—for recruitment of desired stakeholder “types.” To achieve diversity and balance in the stakeholder group, we recruited predetermined types so that the perspective of clinicians, payors, policy, research, and advocacy were represented. Half of the stakeholders we initially invited declined to participate, which meant added time for additional rounds of invitations to achieve a workgroup of 12 members.

Second, allow opportunities for personal interaction among stakeholders. There was a high level of participation during our two teleconferences. To mitigate scheduling conflicts, we included a link for an online availability survey in the invitations. This allowed stakeholders who agreed to participate in the project to indicate their availability for two future teleconferences. The result was a majority of stakeholders joining the teleconferences and high levels of exchange among stakeholders during the two calls.

Throughout the teleconferences and Web-based surveys, stakeholders provided valuable input on research questions and methods and raised important issues for consideration. During the first teleconference, stakeholders were asked to add new items or revise existing items on the list of 12 sample research questions and 12 sample methodologic recommendations. During the discussion, stakeholders raised questions about the importance of “peripheral issues,” such as organizational culture, patient and provider attitudes and preferences, and whether there is sufficient evidence that certain patient, provider and hospital factors influence cesarean use. There was a heavy focus on the need for uniformity of definitions, standards and tracked outcomes related to induction and cesarean. Other items that emerged during the snowballing process (teleconference and web-based survey) were tighter standards for induction and elective cesarean; uniform definitions for arrest of labor; the role of incentives (financial and nonfinancial); and effects of using updated labor curves, peer review systems, audit and feedback, public reporting, novel staffing and scheduling models, and systems-level strategies. Overall, the snowballing process added 35 research questions and 14 recommendations.

During the prioritization phase, stakeholders raised a number of issues. Following the initial voting survey, we held a second teleconference to facilitate discussion of survey results, including the proposed cutpoint of the lowest one-third of items, and reduce any redundancies on the list. During this call, stakeholders raised five issues about the process and survey items:

- Concerns about the initial voting process, specifically the ability of a single stakeholder to influence rankings by concentrating all points on a single item or a few items. This happened with items from the initial voting survey that ranked first and second. The item “What factors drive a patient's decision to undergo a primary cesarean during labor, such as prior cesarean, general fears, fear of future pelvic floor disorders” received all 22 out of 25 points from one voter and ranked first. Similarly, the item “Why do some patients prefer to undergo elective cesarean” received all 23 points from one voter and ranked second.
- Concerns that some items on the list are too similar to be ranked separately.
- Concerns about whether research questions about factors that influence cesarean use are hypothesis driven, that is, are these researchable questions.
- Observations that some of the methodologic improvements listed on the survey are basic clinical trial standards that should be acknowledged and followed by researchers. These items included the following:
  ○ Develop data-driven estimates of plausible decreases in cesarean for use in power calculations.
  ○ Design studies with prespecified secondary outcomes and adequate power for these outcomes.
  ○ Include placebo, sham, or attention control comparison groups, and innovative means of masking patients and providers in studies in interventions.
  ○ Conduct multisite studies to improve applicability and ensure power and precisions. Stakeholders discussed the absence of these basic criteria from the literature, but agreed to remove these items from the list. In the report, the authors would emphasize the importance of these basic consort criteria.

We addressed these issues by explaining that:

1. The initial voting process is a widely used nominal group process and meant to identify priority topics. The process is designed to mimic an in-person group discussion, where participants can promote one topic or many topics. This process is typically followed up with a ranking process that is more consensus driven. We explained that we would followup the initial voting survey with a ranking survey that was designed to give each voter response equal weight.
2. Stakeholders would be able to combine similar items into one survey question during the teleconference.
3. Stakeholders would be able to address this issue in the next two prioritization steps. During the initial ranking, they would be asked to rank research questions in importance from 1 (most important) to 26 (least important). Stakeholders who felt these questions were not hypothesis driven questions could presumably rank them lower than other items. Similarly, stakeholders would be able to address the value of these determinants questions in the final round of prioritization, where they would be asked to rank each item across the seven potential value criteria.

This final prioritization steps resulted in a list of top priority research needs that encompass a variety of topics including (1) tighter standards and definitions for induction and cesarean use (elective and indicated); (2) new measures for labor progress; and (3) trials for systems level strategies to reduce cesarean use and novel staffing models. The top methodologic recommendations focused on improved capture of birth outcomes. Based on the distribution of points across the seven AHRQ criteria, stakeholders gave the most attention to the “potential for significant health impact” and “potential to reduce variation in clinical practices” criteria.

Inherent challenges face investigators and funding agencies who wish to better understand approaches to reduce use of cesarean among low-risk women. Recent reports by the Consortium on Safe Labor, a group of 19 U.S. hospitals conducting an observational study on labor progression and the use and timing of cesareans among women with labor protraction and arrest, show that cesarean birth among women having their first birth has risen to almost one in three.6 Much of this increase occurred in the past decade.1 In the current cultural milieu it cannot be taken for granted that all those who participate in decisions about births and in providing care for women during pregnancy and birth share an objective of reducing use of cesarean.

To obtain meaningful answers that are applicable to the care of women in the United States will require large-scale studies in this country. Several factors suggest this research will need to be predominantly conducted as multisite randomized trials: (1) existing wide variability in use of cesarean means different settings will enter with a different baseline propensity to use cesarean; (2) baseline use patterns are only part of the culture of care at an institution and desire to change use of cesarean likely varies so that interventions need to be shown to be effective across settings; and (3) secular trends in cesarean use, not related to the intervention being studied, impair the ability of observational studies to definitively provide evidence for effectiveness. Some topics, such as investigation of comprehensive midwifery care to reduce cesarean use, will challenge the ability of the care system to identify sufficient numbers of providers across multiple sites who are able and willing to participate in such studies. Furthermore, as the methodologic recommendations of this report suggest, a substantial amount of consensus work needs to be done among researchers, professional organizations, and funders to ensure that the metrics used in research produce data that can be synthesized across families of studies to reach sufficient strength of evidence to inform decisions about care around the nation.

The high priority research needs identified in this project suggest the importance of research at all points along the continuum represented by our analytic framework. Multiple points of influence need to be studied, and the gaps are substantial. The efforts of the stakeholders and our team have identified a multidecade portfolio of questions that need answers.

The high priority research needs identified in this project offer guidance at various points along our analytic framework and the research spectrum—from understanding determinants of cesarean to creating uniform standards and practices for induction and cesarean, exploratory studies, large trials in multiple settings for specific strategies, and creating uniform and expanded panels of outcomes to improve data collection efforts.

## Conclusion

Our multistep process for identifying, multiplying, and prioritizing research questions to advance research in the area of strategies to reduce cesarean birth in low-risk women resulted in an actionable list of research topics to fill specific knowledge gaps. The highest priority research questions encompass many topics of interest, which reflects the large number of gaps in the literature. These topics include: tighter standards and definitions for induction and cesarean use (elective and indicated), new measures for labor progress, and trials that test effectiveness of systems level strategies and novel staffing models. Randomized controlled trials and multisite studies that improve power and generalizability and natural experiments were viewed as critical. The highest priority methodologic recommendations call for improved definitions and tracking of short- and long-term birth outcomes.