# Background

## 2012 AHRQ Comparative Effectiveness Review

This investigation of future research needs for strategies to reduce cesarean birth builds on the work of the Vanderbilt University Evidence-based Practice Center (EPC). The Vanderbilt EPC conducted a comparative effectiveness review (CER) on Strategies To Reduce Cesarean Birth which is scheduled for release in June 2012. The rationale for the review cited specific trends in perinatal health with important public health implications.

Thirty-two percent of pregnancies in the United States conclude with a cesarean birth.1 This record high rate reflects a relative increase of 53 percent in use of cesarean from 1991 to 2007.^1^ The pattern of increasing use of cesarean has been concerning for decades, with the last decline of two to three percent occurring in the mid-1990s being fully reversed by 1999 and increasing more than 50 percent from 1996 to 2007.^2^ Nearly one in three births by cesarean translates to a total of 1.4 million cesarean births each year making cesarean the most commonly performed major surgery in the United States.1

The Joint Commission has expressed concern about U.S. cesarean birth rates in its Specifications Manual for Joint Commission National Quality Core Measures, noting that, “There are no data that higher rates improve any outcomes, yet the CS [cesarean section] rates continue to rise.”7 Cesarean birth is not without consequences. In general, cesarean is more costly to the health care system, is associated with increased risk for both mother and infant, and has potential to complicate subsequent pregnancies.8-9 Previously extraordinarily rare complications such as uterine rupture and abnormalities in placental attachment to the uterus, including placenta accreta and percreta, are becoming more common.10-11 Uterine rupture occurs along the scar line of a prior cesarean and susceptibility is believed to result from relative weakness of the uterine wall at the point of scarring. Placenta accreta and percreta result when placental implantation occurs over or adjacent to scarring, and the placenta invades the uterine muscle more deeply. This is believed to occur because the scarred tissue from a prior cesarean has a less robust blood supply and abnormal architecture at the tissue and cellular level. Indeed, because the effects of these complications can be devastating and include fetal death, emergent hysterectomy, and maternal mortality from associated bleeding, labor and delivery units have created “code teams” that conduct practice drills to be prepared for the increasing number of these emergencies.

Cesarean birth rates vary considerably by geographic region, ranging from 25 to 38 percent among different states with the highest rates in the southeastern United States.1 One research group examining differences across hospitals documented a span from nine percent to 37 percent for primary cesarean births.12 While health care providers and health systems initially viewed such variation as a reflection of underlying differences in the risk profile of the women receiving care at the hospitals, it has become increasingly clear, through use of techniques such as risk adjustment, that a large proportion of variation is real. It is not explained by some facilities having much higher or lower risk patients than others. In medical care, when there is variation of the magnitude we see in use of cesarean after taking into account differences in patient characteristics, the conclusion is that provider preferences, and to a lesser extent patient preferences, are important drivers of variation.13-16

Goals for reducing cesarean in the United States have become less ambitious over time. The Healthy People 2000 goal was to reduce cesarean to 15 percent of all births.17 For Healthy People 2010 this goal was revised to 15 percent among women who had not had a prior cesarean, and in Healthy People 2020 the new target for cesarean among low-risk women in a first pregnancy with a full-term singleton fetus with vertex presentation is 23.9 percent.18-19 The moving target for both numerator and denominator in these goals reflects ambivalence in knowing what the right rate is for optimal maternal and infant outcomes and doubts about what interventions can safely reduce use of cesarean.20-21

Commentary on the factors driving change in cesarean use has been robust. Putative influences include:

- Changes in reimbursement for births that favor interventions such as cesarean22
- Amplified perception of risk of medico-legal liability claims for less than perfect infant outcomes or for failing to intervene23
- Shifts in consumer attitude that include less fear of or regret about cesarean24
- Lower psychosocial or emotional value placed on the experience of vaginal birth25
- Concerns about pelvic floor damage and future continence26-27
- Maternal desire for greater control over the timing and circumstances of birth3 such as maternal request for elective induction and cesarean4

Research has addressed predictors of cesarean such as the shift toward older maternal age, higher body mass index, greater maternal comorbidity, use of assisted reproductive technology, and increased incidence of multiple gestations.28-29

Nonetheless relatively little focus has been placed on research specifically designed to assess strategies to reduce use of cesarean. The notable exception is a study of approaches to promote trial of vaginal birth after prior cesarean (VBAC). Systematic reviews of VBAC interventions report increases in vaginal births from 6 to 70 percent with strategies to support a trial of labor.30-31 The state of general knowledge about evidence-based approaches to reduce cesarean overall is uncharted.

The comparative effectiveness review focused on strategies to reduce cesarean birth in low-risk women who have a singleton pregnancy, vertex presentation, term birth, and no previous cesarean births. The studies assessed strategies implemented specifically with the goal of reducing cesarean birth, including interventions used during prenatal care, during labor, and as part of health systems interventions. Comparators included usual care, placebo, and comparative strategies or combinations of strategies. Outcomes of interest included route of birth, maternal morbidity and mortality, and neonatal morbidity and mortality. Strategies crossed all health care settings, including home, hospital, provider offices, clinics, and community-based settings.

## Key Questions Addressed by 2012 CER

The 2012 AHRQ comparative effectiveness review addressed the following Key Questions (KQs):

- KQ1: What strategies during pregnancy are effective to reduce the use of cesarean birth among women with a singleton pregnancy, who are intending a vaginal birth?
- KQ2: What strategies during labor are effective to reduce the use of cesarean birth among women, with a singleton pregnancy, who are intending a vaginal birth?
- KQ3: Where head-to-head comparisons are available, what strategies are shown to be superior in reducing the use of cesarean birth among women, with a singleton pregnancy, who are intending a vaginal birth?
- KQ4: What are the nature and frequency of adverse effects resulting from strategies used to reduce cesarean birth among women, with a singleton pregnancy, who are intending a vaginal birth?

Three Key Questions (KQ1 through KQ3) seek to identify strategies that reduce the number and/or proportion of cesarean births between comparison groups. The intermediate outcomes include labor progression, need for augmentation, onset of maternal morbidity, and maternal coping and pain management. The final outcomes of most interest include route of birth (comparing number and/or proportion of cesarean births to those that are spontaneous and assisted vaginal). Additional final outcomes included maternal and neonatal morbidity and mortality, Apgar scores, NICU admission, maternal satisfaction, maternal-infant bonding, and breastfeeding success.

Key Question 4 seeks to identify any adverse effects resulting from the use of strategies to reduce cesarean birth. Adverse effects include onset of maternal morbidity, need for additional intervention, and fetal distress.

KQ1 and KQ2. After reviewing the evidence for KQs 1 and 2, the EPC team concluded that no particular intervention strategy was uniformly successful in all trials of the strategy in reducing cesareans. Strength of evidence was low to insufficient across all strategies. Involvement of doulas for personalized support in labor was the only strategy to achieve evidence of benefit which was low due to poor quality of trials.

Several strategies are not supported by the current literature. This does not mean the strategy has no merit and should not be investigated in the future, but does mean that based on the current literature there is not evidence of effectiveness for the purpose of reducing cesarean use among low-risk women. These include measurement of progress in labor as the primary component of intervention, active management of labor, labor support by nursing and midwifery students, modifications of pain management approaches, fetal pulse oximetry, and fetal assessment by ST analysis. For the majority of strategies the evidence is insufficient, including many instances in which a single study is the only evidence about the approach. While certain components of systems-level interventions were common among successful interventions, none were supported by a randomized trial. For each instance of inclusion in a successful pre-post intervention, there were instances of unsuccessful use of similar components.

Deficiencies in the strength of evidence most often related to:

- High proportion of strategies that were represented by only one study, often small, which prevents determination of consistency of findings across studies and populations.
- Preponderance of study designs with high risk of bias in part because means to mask participants and providers to status is challenging.
- Underpowered studies that did not enroll sufficient participants to properly evaluate cesarean as an outcome though reducing cesarean was a stated aim.
- Inconsistent findings across studies; for all strategies in which there was more than one RCT, there was not consistent demonstration of effectiveness.
- Inconsistent selection and definition of outcomes; studies did not consistently report total cesarean, primary cesarean, and repeat cesarean (when applicable), or assisted vaginal births.
- Operational definitions of indications for cesarean are incompatible, or poorly described, across studies so that these outcomes cannot be aggregated with confidence across studies.

KQ3. All studies compared the novel strategy to usual care or to a variation on the same strategy. We did not identify comparisons of distinctive strategies, for instance doula support versus active management of labor, or pain management strategies compared to fetal monitoring strategies. Several comparisons evaluated different approaches to the same strategy such as different approaches to epidural dosing or to monitoring progress of labor. These comparisons of variations on like strategies are noted in the sections that discuss those interventions. For now, there is no evidence to inform prioritization of one type of intervention to another.

KQ4. Few of the adverse effects presented have a direct relationship to the strategy used to prevent cesarean birth. The adverse effects most commonly systematically collected by authors included maternal fever, nausea and vomiting, and anesthesia-related side effects. Many of the studies included in the review, such as those related to psychosocial support, have no known adverse effects.

## Evidence Gaps Identified in Prior Work

The recent comparative effectiveness review on strategies to reduce cesarean birth in low-risk women noted topic-related evidence gaps in the literature and common methodologic issues. These gaps are summarized in Table 1 and categorized by the most relevant PICOTS element(s). Two of the eight topic-related evidence gaps do not fit within the PICOTS framework and are described as “determinants.” These gaps relate to macro-level factors that influence patient, provider, and system preferences about cesarean and decisions to use cesarean. Similarly, two of the nine methodologic issues (Table 2) apply generally to studies and not to a specific PICOTS element. These issues are described as “cross-cutting.”

Table 1 Evidence gaps identified in the Comparative Effectiveness Review

Evidence Gap | Relevant PICOTS Element(s)
Gaps in knowledge about the determinants of cesarean use, including patient, sociocultural, and health care system characteristics | Determinants Timing Setting
Need for qualitative and quantitative research to help determine what factors are contributing to decisions to have elective cesarean | Determinants Timing Setting
Need for multisite research and research across the different racial/ethnic and socioeconomic groups representative of the U.S. population | Population Timing Setting
Need for randomized trials at the systems level to ascertain whether promising intervention components are indeed effective in promoting decreased use of cesarean | Intervention Timing Setting
Need for understanding of the mechanism by which interventions such as doula support exert an effect | Intervention Timing Setting
Gaps in understanding of the effects of staffing models and health care technologies on cesarean rates | Intervention Timing Setting
Need for understanding the role of informed medical decisionmaking | Intervention Timing Setting
Need for understanding the role of tort reform and subsequent litigation cesarean trends | Intervention Timing Setting

Note: PICOTS = population, intervention, comparator, outcome, timing, and setting—refers to the framework used by the Effective Health Care Program to summarize study characteristics.

Table 2 Methodologic issues identified in the Comparative Effectiveness Review

Methodologic Issues | Relevant PICOTS Element
Lack of appropriately powered randomized trials | Cross-cutting
Lack of power calculations based on plausible estimates | Cross-cutting
Need for validated consensus definitions of indications for cesarean | Intervention
Need for placebo, sham, or attention control comparison groups | Comparators
Need for replications and comparisons of promising interventions | Comparators
Need for tracking and reporting of total, primary, and repeat cesareans in studies not restricted to nulliparous women | Outcomes
Lack of secondary outcomes specified a priori | Outcomes
Need for expanded maternal and infant outcomes and measures of maternal coping, satisfaction, and perceived quality of the birth experience | Outcomes
Need for long-term follow up of infants | Outcomes

Note: PICOTS = population, intervention, comparator, outcome, timing, and setting—refers to the framework used by the Effective Health Care Program to summarize study characteristics.

The analytic framework for the 2012 CER has been modified here to illustrate research gaps identified in the report (Figure 1). The framework summarizes how strategies to reduce cesarean before and/or during labor may result in intermediate outcomes such as labor progression, maternal coping, and pain management, and/or long-term outcomes such as route of birth, maternal morbidity and mortality, or neonatal morbidity. It shows how adverse events may occur at any point after the strategy has been implemented. The research gaps described in the framework align with one or more Key Questions. For example, the research gap “determinants of cesarean” appears early in the framework because it applies to all downstream Key Questions.

Figure 1 Analytic framework illustrating research gaps

NICU = Neonatal intensive care unit

Note: Numbers in circles indicate the position of Key Questions in intervention process.

Figure 1 is an analytic framework that summarizes strategies to reduce cesarean birth in low-risk women before and/or during labor, intermediate outcomes such as labor progression, maternal coping, and pain management, and long-term outcomes such as route of birth, maternal morbidity and mortality, or neonatal morbidity. The framework illustrates research gaps identified in the continuing effectiveness review.