# Prioritization Tools and Results

Snowballing Survey

This snowballing survey asked respondents to comment on the 29 research questions of potential utility in reducing use of cesarean sections and the 13 recommendations for methodologic improvements to research on reducing cesarean sections, and to suggest additional research questions and recommendations. The survey also asked several questions to determine respondents' connection to the issue.

Initial Voting Survey

This initial voting survey asked respondents to use a multivoting process to rank, based on importance, the 29 research questions and 13 methodologic improvement recommendations by distributing 47 points among the research questions and 17 points among the methodological improvement recommendations. The ones with fewer points would be eliminated.

Initial Ranking Survey

In this second round of ranking research questions and methodologic improvement recommendations, respondents were asked to rank 25 research questions and 10 methodologic improvement recommendations, which were reduced after the initial voting survey.

Final Ranking Survey

In this final ranking survey, respondents were asked to rank 16 research questions and seven methodologic improvement recommendations from 1 to 5 across seven AHRQ prioritization criteria: potential for significant health impact, potential to reduce variation in clinical practices, potential for significant economic impact, potential risk from inaction, potential to address inequities, potential to allow assessment of ethical, legal, and social issues pertaining to the condition, and potential for new knowledge.

Initial and Final Ranking Results

Table D1 Initial list from Comparative Effectiveness Review

Examples of Research Questions of Potential Utility in Reducing Use of Cesarean
What is the mechanism by which doula support exerts an effect?
Do interventions aimed at disrupting staffing and scheduling phenomena – like the increase in cesarean near change of shifts and differential rates through the week – have promise?
Do different staffing models like use of hospitalists and integration of midwives reduce the number of cesarean births?
Can technologies to enhance fetal surveillance [specify most promising – are there any technology studies worth doing?] improve infant outcomes while reducing cesarean?
What patient and physician factors contribute to use of elective cesarean?
Does use of informed medical decision making models change patient decisions about desire for cesarean or for procedures like induction that may increase risk of cesarean?
Do system level changes applied to all patients in a care setting with the goal of reducing cesarean increase risk of neurodevelopmental delays in children evaluated over years after birth?
As assessed by sociologic models, are current cesarean rates perceived as concerning or not among members of the public, women of childbearing age, obstetrical care providers, payors, and policy makers.
Do natural experiments in tort reform support assertions that liability concerns contribute to use of cesarean?
Does outpatient hyaluronidase injection into the cervix for cervical ripening a term reduce risk of cesarean (replication of single promising trial)?
When strictly operationalized and compared in clinical trials what components of systems intervention are effective?
Does active management of labor, using updated US labor curves, reduce use of cesarean in US community care settings?
Examples of Recommendations for Methodologic Improvements to Research on Reducing Cesarean
Develop data-driven estimates of plausible decreases in cesarean for use in power calculations.
Develop definitions of indications for cesarean that can be validated from medical records and case-report forms.
Include placebo, sham, or attention control comparison groups, and innovative means of masking patients and providers in studies of interventions.
Conduct studies directly comparing and combining candidate strategies to detect additive and multiplicative effects of combining two effective interventions over each effective intervention alone.
Design studies with pre-specified secondary outcomes and adequate power for these outcomes.
Conduct studies that allow stratification on patient characteristics such as nulliparity and multiparity and have adequate power to detect differences across strata.
Track and report total, primary, and repeat cesareans in studies not restricted to nulliparous women.
Capture all categories of birth outcomes (cesarean, emergent cesarean, assisted vaginal and spontaneous births) and related complications in order to assess if reductions in cesarean occur at the cost of increased use of other interventions or increased complications.
Include robust measures of maternal coping, satisfaction, and perceived quality of the birth experience. [Or could be a research question: what scales/indices best capture factors that mothers and partners value about their birth?]
Expand infant outcomes to include a uniform panel of measures that capture infant status better than Apgar scores and NICU admission.
Include maternal length of stay and incidence of specific complications like chorioamnionitis, endometritis, and wound healing complications, as outcomes.
Conduct multisite studies to improve applicability and assure power and precision.

Table D2 Snowballing Survey results

Research Questions
1. | Why do some patients prefer to undergo elective cesarean?
2. | What factor's drive a patient's decision to undergo a primary cesarean during labor, e.g. prior cesarean, general fears, fear of future pelvic floor disorders?
3. | What patient preferences influence decisions to convert to primary cesarean during labor, e.g. pain management, progress of labor, fears about baby's well-being?
4. | What physician factors contribute to use of elective cesarean, e.g. residency training, attitude toward elective cesarean, practice size, practice setting, shift/time of day, use of hospitalists, personal birth experience?
5. | What physician factors contribute to use of cesarean during labor, e.g. residency training, attitude toward elective cesarean, practice size, practice setting, shift/time of day, use of hospitalists, personal birth experience?
6. | To what extent do nonfinancial incentives such as time savings, control and perceived improvement in patient relations affect physician decisions to use cesarean?
7. | What nurse or midwife factors contribute to the use of cesarean during labor?
8. | What nurse or midwife factors contribute to the use of elective cesarean?
9. | What hospital factors contribute to the use of cesarean during labor, e.g. teaching status, geographical region, urban location, socioeconomic status of patients, staffing and scheduling patters, provider attitudes toward cesarean use?
10. | What hospital factors contribute to the use of elective cesarean, e.g. teaching status, geographical region, urban location, socioeconomic status of patients, staffing and scheduling patters, provider attitudes toward cesarean use?
11. | Do audit and feedback interventions influence physician use of cesarean?
12. | Do interventions aimed at disrupting staffing and scheduling phenomena - like the increase in cesarean near change of shifts and differential rates through the week - have promise?
13. | Does cesarean use correlate with specific days of the week or time of day?
14. | Do different staffing models like use of hospitalists and integration of midwives reduce the number of cesarean births?
15. | Do provider peer-review models change provider patterns of cesarean use?
16. | Do natural experiments in tort reform support assertions that liability concerns contribute to use of cesarean?
17. | Do natural experiments in payment reform support the assertions that certain incentive structures contribute to the use of cesarean?
18. | To what degree is use of cesarean driven by uniform compensation for vaginal and cesarean birth as tested by an RCT?
19. | Does public reporting of hospital primary and total cesarean rates affect hospital cesarean rates over time?
20. | Does public reporting of physician primary and total cesarean rates affect physician use of cesarean over time?
21. | Does public reporting of physician primary and total cesarean rates affect physician use of induction over time?
22. | Does use of informed medical decision making models change patient decisions about desire for cesarean or for procedures like induction that may increase risk of cesarean?
23. | Is the Bishop's score routinely used by providers as a decision making tool? If not, why not?
24. | To what extent to patient educational and support tools affect patient decisions to undergo elective cesarean?
25. | To what extent do educational tools that manage patient expectations and describe the risks of cesarean influence use of cesareans during labor?
26. | Do system level changes applied to all patients in a care setting with the goal of reducing cesarean increase risk of neurodevelopmental delays in children evaluated over years after birth?
27. | When strictly operationalized and compared in clinical trials what components of systems intervention are effective in reducing cesarean use?
28. | Can technologies to enhance fetal surveillance [specify most promising - are there any technology studies worth doing?] improve infant outcomes while reducing cesarean?
29. | Does a protocol for use of scalp pH sampling reduce use of cesarean?
30. | Does outpatient hyaluronidase injection into the cervix for cervical ripening at term reduce risk of cesarean (replication of single promising trial)?
31. | Does active management of labor, using updated US labor curves, reduce use of cesarean in US community care settings?
32. | Does use of the Consortium for Safe Labor labor curves reduce use of cesarean?
33. | Does elective induction at 39 weeks vs. expectant management at 39 weeks influence use of cesarean?
34. | Can protocols supporting trial of induction of labor make it realistic for physicians to send a patient home if induction of labor does not progress in a timely fashion?
35. | What is the mechanism by which doula support exerts an effect?
36. | Does midwifery care through-out pregnancy in a hospital setting reduce use of cesarean among low-risk women when compared in a randomized clinical trial to obstetric care?
37. | Does midwifery care in labor in a hospital setting reduce use of cesarean among low-risk women when compared in a randomized clinical trial to obstetric care?
38. | Can tighter standards for elective induction among primiparous patients reduce use of cesarean?
39. | Can tighter standards for indicated induction among primiparous patients reduce use of cesarean?
40. | How does implementing uniform definitions for arrest of labor and its management influence use of cesarean?
41. | How does implementing a standard indication list affect physicians' use of cesarean?
42. | Would changing the definition of when active labor starts reduce use of cesarean?
43. | Would changing the timeframes for normal progress in latent and active labor reduce primary cesareans?
44. | Would a tighter definition of elective cesarean affect physicians' use of cesarean?
45. | What scales/indices best capture factors that mothers and partners value about their birth?
46. | As assessed by sociologic models, to what extent are cesarean rates perceived as concerning or not among members of the public, women of childbearing age, obstetrical care providers, payors, and policy makers?
47. | What factors have resulted in the change in patterns of the diagnosis of dystocia over the decades?
Methodologic Recommendations
1. | Develop data-driven estimates of plausible decreases in cesarean for use in power calculations.
2. | Develop definitions of indications for cesarean that can be validated from medical records and case-report forms.
3. | Include placebo, sham, or attention control comparison groups, and innovative means of masking patients and providers in studies of interventions.
4. | Conduct studies directly comparing and combining candidate strategies to detect additive and multiplicative effects of combining two effective interventions over each effective intervention alone.
5. | Design studies with pre-specified secondary outcomes and adequate power for these outcomes.
6. | Conduct studies that allow stratification on patient characteristics such as nulliparity and multiparity and have adequate power to detect differences across strata.
7. | Track and report total, primary, and repeat cesareans in studies not restricted to nulliparous women.
8. | Capture all categories of birth outcomes (cesarean, emergent cesarean, assisted vaginal and spontaneous births) and related complications in order to assess if reductions in cesarean occur at the cost of increased use of other interventions or increased complications.
9. | Include robust measures of maternal coping, satisfaction, and perceived quality of the birth experience.
10. | Expand infant outcomes to include a uniform panel of measures that capture infant status and development better than Apgar scores and NICU admission, including post-discharge measures.
11. | Include maternal length of stay and incidence of specific complications like chorioamnionitis, endometritis, and wound healing complications, as outcomes in studies.
12. | Conduct multisite studies to improve applicability and assure power and precision.
13. | Conduct larger trials of health system interventions.
14. | Develop registries that capture both long term and short term outcomes.
15. | Determine the best measures of patient and provider route of birth preferences.
16. | Consider the relationship between refined definitions of indications for cesarean and existing population based measures (e.g. hospital discharge data) to better identify algorithms that can be used to document indications in both clinical and nonclinical databases.
17. | Future studies should include a full range of practice settings including community hospitals and birth centers.

Table D3 Initial voting results: Research questions

Research Questions | Total Points
What factors drive a patient's decision to undergo a primary cesarean during labor, e.g. prior cesarean, general fears, fear of future pelvic floor disorders? | 25 (22 from 1 vote)
Why do some patients prefer to undergo elective cesarean? | 23 (23 from 1 vote)
Do different staffing models like use of hospitalists and integration of midwives reduce the number of cesarean births? | 21
What physician factors contribute to the use of cesarean during labor, e.g. residency training, attitude toward cesarean, practice setting, practice size, shift/time of day, use of hospitalists, personal birth experience? | 20
Does use of the Consortium for Safe Labor labor curves reduce use of cesarean? | 18
Does elective induction at 39 week vs. expectant management at 39 weeks influence use of cesarean? | 18
Can tighter standards for [underlined: elective induction] among primiparous patients reduce use of cesarean? | 18
To what extent do nonfinancial incentives such as time savings, control and perceived improvement in patient relations affect physician decisions to use cesarean? | 17
Do audit and feedback interventions influence physician use of cesarean? | 17
To what extent do educational tools that manage patient expectations and describe the risks of cesarean influence use of cesareans during labor? | 17
Does midwifery care in labor in a hospital setting reduce use of cesarean among low-risk women when compared in a randomized clinical trial to obstetric care? | 17
Can tighter standards for [underlined: indicated induction] among primiparous patients reduce use of cesarean? | 17
Does use of informed medical decision making models change patient decisions about desire for cesarean or for procedures like induction that may increase risk of cesarean? | 16
Would changing the definition of when active labor starts reduce use of cesarean? | 16
Would changing the timeframes for normal progress in latent and active labor reduce primary cesareans? | 16
Does public reporting of individual physician primary and total cesarean rates affect physician use of [underlined: cesarean] over time? | 14
What hospital factors contribute to the use of cesarean during labor, e.g. teaching status, geographical region, urban location, socioeconomic status of patients, staffing and scheduling pattern, provider attitudes toward cesarean use? | 13
To what degree is use of cesarean driven by uniform compensation for vaginal and cesarean birth as tested by an RCT? | 13
How does implementing uniform definitions for arrest of labor and its management influence use of cesarean? | 13
Do provider peer-review models change provider patterns of cesarean use? | 12
Does public reporting of hospital primary and total cesarean rates affect hospital [underlined: cesarean rates] over time? | 12
What physician factors contribute to the use of elective cesarean, e.g. residency training, attitude toward elective cesarean, practice size, practice setting, shift/time of day, use of hospitalists, personal birth experience? | 11
Does a protocol for use of scalp pH sampling reduce use of cesarean? | 11
Does midwifery care through-out pregnancy in a hospital setting reduce use of cesarean among low-risk women when compared in a randomized clinical trial to obstetric care? | 11
What nurse or midwife factors contribute to the use of cesarean during labor? | 10
Do natural experiments in [underlined: payment reform] support the assertions that certain incentive structures contribute to the use of cesarean? | 10
What factors have resulted in the change in patterns of the diagnosis of dystocia over the decades? | 10
Do natural experiments in [underlined: tort reform] support assertions that liability concerns contribute to use of cesarean? | 9
To what extent do patient educational and decision support tools affect patient decisions to undergo elective cesarean? | 9
When strictly operationalized and compared in clinical trials what components of systems intervention are effective in reducing cesarean use? | 9
Does public reporting of hospital primary and total cesarean rates affect hospital [underlined: induction rates] over time? | 8
Does public reporting of individual physician primary and total cesarean rates affect physician use of [underlined: induction] over time? | 8
Do interventions aimed at disrupting staffing and scheduling phenomena - like the increase in cesarean near change of shifts and differential rates through the week - have promise? | 7
As assessed by sociologic models, to what extent are cesarean rates perceived as concerning or not among members of the public, women of childbearing age, obstetrical care providers, payors, and policy makers? | 7
What patient preferences influence decisions to convert to primary cesarean during labor, e.g. pain management, progress of labor, fears about baby's well-being? | 6
What hospital factors contribute to the use of [underlined: elective cesarean], e.g. teaching status, geographical region, urban location, socioeconomic status of patients, staffing and scheduling pattern, provider attitudes toward cesarean use? | 6
Do system level changes applied to all patients in a care setting with the goal of reducing cesarean increase risk of neurodevelopmental delays in children evaluated over years after birth? | 6
Does use of cesareans correlate with specific days of the week or time of day? | 4
Is the Bishop's score routinely used by providers as a decision making tool? If not, why not? | 4
Can technologies to enhance fetal surveillance [specify most promising - are there any technology studies worth doing?] improve infant outcomes while reducing cesarean? | 4
Can protocols supporting trial of induction of labor make it realistic for physicians to send a patient home if induction of labor does not progress in a timely fashion? | 3
Does outpatient hyaluronidase injection into the cervix for cervical ripening at term reduce risk of cesarean (replication of single promising trial)? | 2
Does active management of labor, using updated US labor curves, reduce use of cesarean in US community care settings? | 2
How does implementing a standard indication list affect physician's use of cesarean? | 2
What nurse or midwife factors contribute to the use of elective cesarean? | 1
What is the mechanism by which doula support exerts an effect? | 1
Would a tighter definition of elective cesarean affect physician's use of cesarean? | 0

Items highlighted in pink represent the lower-third responses that were eliminated from the priority list.

Table D4 Initial voting results: Methodologic recommendations

Methodologic Recommendations | Total Points
Capture all categories of birth outcomes (cesarean, emergent cesarean, assisted vaginal and spontaneous births) and related complications in order to assess if reductions in cesarean occur at the cost of increased use of other interventions or increased complications. | 21
Conduct studies that allow stratification on patient characteristics such as nulliparity and multiparity and have adequate power to detect differences across strata. | 13
Conduct larger trials of health system interventions. | 13
Develop definitions of indications for cesarean that can be validated from medical records and case-report forms. | 12
Expand infant outcomes to include a uniform panel of measures that capture infant status and development better than Apgar scores and NICU admission, including post-discharge measures. | 11
Develop registries that capture both short term and long term outcomes. | 11
Future studies should include a full range of practice settings including community hospitals and birth centers. | 11
Include robust measures of maternal coping, satisfaction, and perceived quality of the birth experience. | 8
Develop data-driven estimates of plausible decreases in cesarean for use in power calculations. | 7
Design studies with pre-specified secondary outcomes and adequate power for these outcomes. | 7
Track and report total, primary, and repeat cesareans in studies not restricted to nulliparous women. | 7
Determine the best measures of patient and provider route of birth preferences. | 7
Consider the relationship between refined definitions of indications for cesarean and existing population based measures (e.g. hospital discharge data) to better identify algorithms that can be used to document indications in both clinical and nonclinical databases. | 7
Conduct studies directly comparing and combining candidate strategies to detect additive and multiplicative effects of combining two effective interventions over each effective intervention alone. | 5
Include maternal length of stay and incidence of specific complications like chorioamnionitis, endometritis, and wound healing complications, as outcomes in studies. | 5
Include placebo, sham, or attention control comparison groups, and innovative means of masking patients and providers in studies of interventions. | 2
Conduct multisite studies to improve applicability and assure power and precision. | 2

Items highlighted in pink represent the lower-third responses that were eliminated from the priority list.

Table D5 Initial ranking results: Research questions

Research Questions | Total Points
Can tighter standards for induction (indicated or elective) among primiparous patients reduce use of cesarean? | 76
Do different staffing models, e.g. models that use hospitalists or midwives, reduce the number of cesarean births? | 85
How does implementing uniform definitions for arrest of labor and its management influence use of cesarean? | 86
Would changing the timeframes for normal progress in latent and active labor reduce primary cesareans? | 86
What physician factors contribute to the use of cesarean during labor, e.g. residency training, attitude toward cesarean, practice setting, practice size, shift/time of day, use of hospitalists, personal birth experience? | 95
Does elective induction at 39 weeks vs. expectant management at 39 weeks influence use of cesarean? | 95
Does use of the Consortium for Safe Labor labor curves reduce use of cesarean? | 106
To what extent do educational and decision support tools that manage patient expectations and describe the risks of cesarean influence use of induction, elective cesarean and cesareans during labor? | 114
To what extent do nonfinancial incentives such as time savings, control and perceived improvement in patient relations affect physician decisions to use cesarean? | 115
When strictly operationalized and compared in clinical trials, what components of systems interventions are effective in reducing cesarean use? | 116
Does public reporting affect induction and cesarean rates over time, e.g. public reporting of total and primary cesarean rates for individual physicians, public reporting of primary and total cesarean rates for hospitals? | 119
Do audit and feedback interventions influence physician use of cesarean? | 121
Do natural experiments in payment reform support the assertions that certain incentive structures contribute to the use of cesarean? | 136
What hospital factors contribute to the use of cesarean, e.g. teaching status, geographical region, urban location, socioeconomic status of patients, staffing and scheduling pattern, provider attitudes toward cesarean use? | 137
What factors drive a patient's decision to undergo a primary cesarean during labor, e.g. prior cesarean, fears, satisfaction with progress of labor, satisfaction with pain management, etc.? | 142
Does midwifery care throughout pregnancy in a hospital setting reduce use of cesarean among low-risk women when compared in a randomized clinical trial to obstetric care? | 151
As assessed by sociologic models, to what extent are cesarean rates perceived as concerning or not among members of the public, women of childbearing age, obstetrical care providers, payors, and policy makers? | 152
What nurse or midwife factors contribute to the use of cesarean during labor? | 170
What factors have resulted in the change in patterns of the diagnosis of dystocia over the decades? | 171
Can protocols supporting trial of induction of labor make it realistic for physicians to send a patient home if indication of labor does not progress in a timely fashion? | 171
Does a protocol for use of scalp pH sampling reduce use of cesarean? | 177
Do provider peer-review models change provider patterns of cesarean use? | 179
Do natural experiments in [underlined: tort reform] support assertions that liability concerns contribute to use of cesarean? | 185
Do system level changes applied to all patients in a care setting with the goal of reducing cesarean increase risk of neurodevelopmental delays in children evaluated over years after birth? | 187
Do interventions aimed at disrupting staffing and scheduling phenomena - like the increase in cesarean near change of shifts and differential rates through the week - have promise? | 214

Items highlighted in pink represent the lower-third responses that were eliminated from the priority list.

Table D6 Initial ranking results: Methodologic recommendations

Methodologic Recommendations | Total Points
Capture all categories of birth outcomes (primary and repeat cesarean, emergent cesarean, assisted vaginal and spontaneous births) and related complications and stratify outcomes by parity. | 21
Future studies should include a full range of practice settings including community hospitals, birth centers and health systems. | 40
Develop definitions of indications for cesarean that can be validated from medical records and case-report forms. | 44
Develop registries that capture both short term and long term outcomes. | 45
Include in studies maternal health outcomes, including maternal length of stay and incidence of specific complications like chorioamnionitis, endometritis, and wound healing complications. | 45
Expand infant outcomes to include a uniform panel of measures that capture infant status and development better than Apgar scores and NICU admission, including post-discharge measures. | 49
Determine the best measures of patient and provider route of birth preferences. | 61
Include robust measures of maternal coping, satisfaction, and perceived quality of the birth experience. | 64
Conduct studies directly comparing and combining candidate strategies to detect additive and multiplicative effects of combining two effective interventions over each effective intervention alone. | 66
Consider the relationship between refined definitions of indications for cesarean and existing population based measures (e.g. hospital discharge data) to better identify algorithms that can be used to document indications in both clinical and nonclinical databases. | 70

Items highlighted in pink represent the lower-third responses that were eliminated from the priority list.

Table D7 Final prioritization results: Research questions

| AHRQ Potential Value Criteria
Research Questions | Health impact | Reduce variation | Economic impact | Risk from inaction | Address inequities | Ethical, legal, social | New knowledge | Total Points | Tier
When strictly operationalized and compared in clinical trials, what components of systems interventions are effective in reducing cesarean use? | 45 | 43 | 40 | 32 | 28 | 25 | 40 | 253 | Top
Can tighter standards for induction (indicated or elective) among pimiparous patients reduce use of cesarean? | 43 | 44 | 33 | 38 | 34 | 28 | 32 | 252 | Top
How does implementing uniform definitions for arrest of labor and its management influence use of cesarean? | 41 | 47 | 35 | 34 | 31 | 25 | 35 | 248 | Top
Would changing the timeframes for normal progress in latent and active labor reduce primary cesarean? | 41 | 46 | 34 | 29 | 30 | 26 | 35 | 241 | Top
Do different staffing models, e.g. models that use hospitalists or midwives, reduce the number of cesarean births? | 42 | 39 | 39 | 30 | 29 | 26 | 34 | 239 | Top
Does midwifery care through-out pregnancy in a hospital setting reduce use of cesarean among low-risk women when compared in a randomized clinical trial to obstetric care? | 40 | 34 | 35 | 29 | 31 | 25 | 33 | 227 | Middle
Do natural experiments in payment reform support the assertions that certain incentive structures contribute to the use of cesarean? | 37 | 34 | 36 | 29 | 28 | 32 | 29 | 225 | Middle
To what extent do educational and decision support tools that manage patient expectations and describe the risks of cesarean influence use of induction, elective cesarean and cesareans during labor? | 36 | 34 | 30 | 28 | 32 | 31 | 31 | 222 | Middle
Does elective induction at 39 weeks vs. expectant management at 39 weeks influence use of cesarean? | 36 | 38 | 35 | 27 | 29 | 26 | 26 | 217 | Middle
What physician factors contribute to the use of cesarean during labor, e.g. residency training, attitude toward cesarean, practice setting, practice size, shift/time of day, use of hospitalists, personal birth experience? | 36 | 34 | 31 | 26 | 28 | 28 | 33 | 216 | Middle
Does use of the Consortium for Safe Labor labor curves reduce use of cesarean? | 36 | 38 | 29 | 26 | 27 | 23 | 33 | 212 | Middle
What factors drive a patient's decision to undergo a primary cesarean during labor, e.g. prior cesarean, fears, satisfaction with progress of labor, satisfaction with pain management, etc? | 35 | 30 | 30 | 23 | 29 | 35 | 29 | 211 | Middle
Does public reporting affect induction and cesarean rates over time, e.g. public reporting of total and primary cesarean rates for individual physicians, public reporting of primary and total cesarean rates for hospitals? | 35 | 31 | 33 | 28 | 29 | 25 | 30 | 211 | Middle
Do audit and feedback interventions influence physician use of cesarean? | 36 | 36 | 31 | 28 | 27 | 26 | 24 | 208 | Middle
To what extent do nonfinancial incentives such as time savings, control and perceived improvement in patient relations affect physician decisions to use cesarean? | 33 | 31 | 32 | 26 | 28 | 29 | 27 | 206 | Middle
What hospital factors contribute to the use of cesarean during labor, e.g. teaching status, geographical region, urban location, socioeconomic status of patients, staffing and scheduling pattern, provider attitudes toward cesarean use? | 32 | 29 | 27 | 26 | 26 | 25 | 24 | 189 | Lower

Table D8 Final prioritization results: Methodologic recommendations

| AHRQ Potential Value Criteria
Methodologic Recommendations | Health impact | Reduce variation | Economic impact | Risk from inaction | Address inequities | Ethical, legal, social | New knowledge | Total Points | Tier
Capture all categories of birth outcomes (primary and repeat cesarean, emergent cesarean, assisted vaginal and spontaneous births) and related complications and stratify outcomes by parity. | 49 | 43 | 38 | 40 | 36 | 36 | 39 | 281 | Top
Develop registries that capture both short term and long term outcomes. | 48 | 43 | 38 | 33 | 33 | 34 | 40 | 269 | Top
Future studies should include a full range of practice settings including community hospitals, birth centers and health systems. | 45 | 41 | 35 | 33 | 37 | 31 | 36 | 258 | Middle
Expand infant outcomes to include a uniform panel of measures that capture infant status and development better than Apgar scores and NICU admission, including post-discharge measures. | 45 | 42 | 37 | 33 | 32 | 29 | 38 | 256 | Middle
Develop definitions of indications for cesarean that can be validated from medical records and case-report forms. | 45 | 41 | 33 | 31 | 29 | 27 | 32 | 238 | Middle
Include in studies maternal health outcomes, including maternal length of stay and incidence of specific complications like chorioamnionitis, endometritis, and wound healing complications. | 39 | 33 | 36 | 29 | 28 | 25 | 35 | 225 | Lower
Determine the best measures of patient and provider route of birth preferences. | 34 | 29 | 31 | 28 | 30 | 33 | 31 | 216 | Lower

Table D9 Top-five items for each AHRQ criterion^*^

| AHRQ Criteria
Research Question | Health impact | Reduce variation | Economic impact | Risk from inaction | Address inequities | Ethical, legal, social | New knowledge | Tier
When strictly operationalized and compared in clinical trials, what components of systems interventions are effective in reducing cesarean use? | ✓ | ✓ | ✓ | ✓ | | | ✓ | Top
Can tighter standards for induction (indicated or elective) among pimiparous patients reduce use of cesarean? | ✓ | ✓ | | ✓ | ✓ | ✓ | ✓ | Top
How does implementing uniform definitions for arrest of labor and its management influence use of cesarean? | ✓ | ✓ | ✓ | ✓ | ✓ | | ✓ | Top
Would changing the timeframes for normal progress in latent and active labor reduce primary cesarean? | ✓ | ✓ | | ✓ | ✓ | | ✓ | Top
Do different staffing models, e.g. models that use hospitalists or midwives, reduce the number of cesarean births? | ✓ | ✓ | ✓ | ✓ | ✓ | | ✓ | Top
Does midwifery care through-out pregnancy in a hospital setting reduce use of cesarean among low-risk women when compared in a randomized clinical trial to obstetric care? | ✓ | | ✓ | ✓ | ✓ | | ✓ | Middle
Do natural experiments in payment reform support the assertions that certain incentive structures contribute to the use of cesarean? | | | ✓ | ✓ | | ✓ | | Middle
To what extent do educational and decision support tools that manage patient expectations and describe the risks of cesarean influence use of induction, elective cesarean and cesareans during labor? | | | | | ✓ | ✓ | | Middle
Does elective induction at 39 weeks vs. expectant management at 39 weeks influence use of cesarean? | | | | | ✓ | | | Middle
What physician factors contribute to the use of cesarean during labor, e.g. residency training, attitude toward cesarean, practice setting, practice size, shift/time of day, use of hospitalists, personal birth experience? | | | | | | ✓ | ✓ | Middle
Does use of the Consortium for Safe Labor labor curves reduce use of cesarean? | | | | | | | ✓ | Middle
What factors drive a patient's decision to undergo a primary cesarean during labor, e.g. prior cesarean, fears, satisfaction with progress of labor, satisfaction with pain management, etc? | | | | | ✓ | ✓ | | Middle
Does public reporting affect induction and cesarean rates over time, e.g. public reporting of total and primary cesarean rates for individual physicians, public reporting of primary and total cesarean rates for hospitals? | | | | | ✓ | | | Middle
Do audit and feedback interventions influence physician use of cesarean? | | | | | | | | Middle
To what extent do nonfinancial incentives such as time savings, control and perceived improvement in patient relations affect physician decisions to use cesarean? | | | | | | ✓ | | Middle
What hospital factors contribute to the use of cesarean during labor, e.g. teaching status, geographical region, urban location, socioeconomic status of patients, staffing and scheduling pattern, provider attitudes toward cesarean use? | | | | | | | | Lower

* This table presents research questions with checkmarks to indicate those items that appear in the top-five for [underlined: each specific] AHRQ criterion. An AHRQ criterion with more than five checked items reflects tied rankings for two or more of the items. The tier assigned (last column) to each research question is based on total points assigned for [underlined: all seven] AHRQ criteria.

Table D10 Top-tier methodologic recommendations

| AHRQ Criteria
Methodologic Recommendations | Health impact | Reduce variation | Economic impact | Risk from inaction | Address inequities | Ethical, legal, social | New knowledge | Tier
Capture all categories of birth outcomes (primary and repeat cesarean, emergent cesarean, assisted vaginal and spontaneous births) and related complications and stratify outcomes by parity. | ✓ | ✓ | ✓ | ✓ | ✓ | ✓ | ✓ | Top
Develop registries that capture both short term and long term outcomes. | ✓ | ✓ | ✓ | ✓ | | ✓ | ✓ | Top
Future studies should include a full range of practice settings including community hospitals, birth centers and health systems. | | | | ✓ | ✓ | | | Middle
Expand infant outcomes to include a uniform panel of measures that capture infant status and development better than Apgar scores and NICU admission, including post-discharge measures. | | | ✓ | ✓ | | | | Middle
Develop definitions of indications for cesarean that can be validated from medical records and case-report forms. | | | | | | | | Middle
Include in studies maternal health outcomes, including maternal length of stay and incidence of specific complications like chorioamnionitis, endometritis, and wound healing complications. | | | | | | | | Lower
Determine the best measures of patient and provider route of birth preferences. | | | | | | | | Lower

* This table presents research questions with checkmarks to indicate those items that appear in the top-two for [underlined: each specific] AHRQ criterion. An AHRQ criterion with more than two checked items reflects tied rankings for two or more of the items. The tier assigned (last column) to each research question is based on total points assigned for [underlined: all seven] AHRQ criteria.