# Stakeholder Invitation Letter

My name is Dr. Katherine Hartmann. As Director of the Vanderbilt Evidence-based Practice Center I am writing to invite you to participate in a research study. The Agency for Healthcare Research and Quality (AHRQ) is undertaking a concerted effort to further develop the Future Research sections of its systematic reviews. To that end the Vanderbilt Evidence-based Practice Center (EPC) is conducting a project to expand and prioritize the knowledge gaps and research needs identified in the Future Research section of the Comparative Evidence Review of Strategies to Reduce Cesarean Birth.

You have been identified as a stakeholder with interests and experience relevant to reducing use of cesarean in one or more of the following areas:

1. Advocacy
2. Clinical practice
3. Research
4. Research funding priorities

Your involvement could include participation in one or more of the following activities (you are not required to participate in all components of the research to participate in the project):

1. Participating in a one-hour conference call to expand a list of research needs related to reducing use of cesarean.
2. Prioritizing of these research needs via a web-based ranking system (two week access to online site).
3. Participating in a second group conference call (one hour) to refine the list of prioritized research needs.
4. Prioritizing the refined list of needs via web-based ranking system (two week access to online site).
5. Reviewing the Strategies to Reduce Cesarean Births Future Research Needs report (participants will have four weeks to review and comment on the report available on a public web site).

Please let us know via email by February 15, 2012 if you are willing to participate by contacting Rashonda Lewis at rashonda.m.lewis@vanderbilt.edu or 615-936-2653. If you are able to participate we request that you complete the attached Doodle to indicate your availability for our first meeting.

Doodle link: http://www.doodle.com/7sribep32kdxdaay

Participation is voluntary:

Participation in this project is completely voluntary, and you may discontinue your participation at any time. Approximately 12 stakeholders will be asked to participate in one or more of the activities listed above.

Confidentiality:

All the information we receive from you, including your name and any other identifying information (if applicable), will be strictly confidential and will be on password protected server maintained by computer services at Vanderbilt University. We will not use any information that would make it possible for anyone to identify the opinions you contributed in any presentation or written report about this project. Conference calls will be recorded so that a comprehensive transcript can be produced. Digital files of the recordings will be destroyed upon completion of the transcript approximately 7-10 days after the call, and names and other identifying information will be deleted from all electronic and paper copies of transcripts. Written consent will be required before you can participate in any project activities. Since names are not required as part of the study data, no identifying information, such as the participants' names will be part of study data. If this information is recorded on phone conversations or documents we receive from you it will be kept only to determine that we have received all responses and will be destroyed or deleted within 7 days of the submission of the final report on or about August 15, 2012.

Risks and Benefits of Participating:

There is a slight risk your organization's name could be disclosed, but all efforts are made to reduce this possibility. The benefit of participating in this project is the knowledge that you are assisting AHRQ and the Vanderbilt Evidence-based Practice Center in moving forward research related to strategies to reducing use of cesareans. Lists and rankings of research needs from each participant will be combined and a summary of this information will be generated by analysts at the Vanderbilt EPC. No individual names will be mentioned in the summary.

If you have questions about this project:

If you have questions about this project, you may “reply” to this email and we will respond to your questions as soon as possible. You may also call us at 615-936-2653.

If you have questions about the rights of participants in a research project, you may contact the Vanderbilt Institutional Review Board directly at 1-866-224-8273 or www.mc.vanderbilt.edu/irb.

Thank you for considering participating in this project.

Regards—

Rashonda M. Lewis, JD, MHA

Investigator, Vanderbilt Evidence-based Practice Center

Healthcare Liaison, Davidson County, TN National Children's Study Center

Institute for Medicine and Public Health

2525 West End Ave, Suite 600, Sixth Floor

Nashville, TN 37203-1738

Phone: (615) 936-2653

Fax: (615) 936-8291

rashonda.m.lewis@vanderbilt.edu

For

Katherine E. Hartmann, MD, PhD

Lucius M. Burch Professor of Obstetrics and Gynecology

Associate Dean for Clinical and Translational Scientist Development

Director, Vanderbllt AHRQ Evidence-based Practice Center

Deputy Director, Institute for Medicine and Public Health