# Acknowledgments

We are indebted to the stakeholders who committed time, expertise, and thoughtful insight to this project. We appreciate the support of the AHRQ Task Officer, Shilpa Amin, M.D., M.BSc., FAAFP. Finally, we acknowledge the extraordinary contributions of our colleagues at the Vanderbilt Evidence-based Practice Center, authors of the 2012 Comparative Effectiveness Review, Strategies To Reduce Cesarean Birth in Low-Risk Women.