# Abbreviations

AHRQ: Agency for Healthcare Research and Quality
CER: Comparative Effectiveness Review
EHC: Effective Health Care
EBM: Evidence-based medicine
EPC: Evidence-based Practice Center
KQ: Key Question
NICU: Neonatal intensive care unit
PiCMe: Prioritization Criteria Method
PSCOS: Population, Strategy, Comparator, Outcome, Setting
RCT: Randomized clinical trial
VBAC: Vaginal birth after cesarean