# Results

## Stakeholders

Stakeholders represented clinical, research, and advocacy perspectives in PKU. The panel comprised nine stakeholders, including a physician from a pharmaceutical company, an advocate who has children with PKU, representatives from government agencies that fund research on developmental disabilities, a dietician and nutritionist, clinical researchers with expertise in generics and metabolism, and experts in developmental medicine and in bioethics. Appendix E includes a summary of discussion from the initial stakeholder call

## Research Needs

### Needs Identified in CER and via Stakeholder Input

Table 4 lists the research needs identified in the CER and those generated via stakeholders organized by Key Question. Where identified, possibly relevant ongoing research is included.

Table 4 Research needs identified in CER and by stakeholders

Key Question | Research Question | Potentially Relevant Ongoing Research
1a. What is the evidence that any specific Phe levels are optimal for minimizing or avoiding cognitive impairment in individuals with PKU? 1b. What is the evidence that different target Phe levels are appropriate for minimizing or avoiding cognitive impairment for different age groups? | Which domains of executive function (e.g., planning, inhibitory control) are most sensitive to changes in Phe in individuals with PKU? | None identified
| Which measures, including executive function and affective disorder screens, are shown to be associated with to changes in cognitive outcomes related to Phe level in individuals with PKU? | None identified
| To what degree do measures of executive function vary with cognition, in the context of varying levels of Phe? | None identified
| What is the validity, reliability, and responsiveness to change of existing tools for measuring executive function in individuals with PKU? | None identified
| When measuring executive function in individuals with PKU, when and how frequently should these measures be assessed? | None identified
| Which measures of ADHD are valid, sensitive, and reliable for use in individuals with PKU?^*^ | None identified
| What are the clinical benefits and limitations of distinguishing attention-related symptoms due to elevated Phe levels vs. from non-PKU-related factors such as individual behavior?^*^ | None identified
| To what degree does Phe level affect domains of social and emotional functioning in PKU?^*^ | None identified
| What is the relationship between clinical measures of executive function and “real world”/adaptive functioning?^*^ | None identified
| What are the effects of nutritional status on measures of executive function or emotion?^*^ | None identified
| To what extent are poor cognitive outcomes related to dietary deficiencies compared with Phe levels?^*^ | None identified
2. What is the comparative effectiveness of BH4 with dietary intervention versus dietary intervention alone for affecting outcomes including measures of cognition (including executive function), quality of life, and nutritional status? | In children ≤4 years old with PKU, what is the effect of BH4 plus diet compared with placebo plus diet/standard care on Phe control, cognitive outcomes (IQ and measures of executive function), QOL, liberalization of diet, and growth and development? | - PKUDOS: Phenylketonuria (PKU) Demographic, Outcomes, and Safety Registry (NCT00778206); - Kuvan^®^ Adult Maternal Pediatric European Registry (KAMPER): Observational Study on the Long Term Safety of Kuvan^®^ Treatment in Patients With Hyperphenylalaninemia (HPA) Due to Phenylketonuria (PKU) or BH4 Deficiency (NCT01016392); - Safety, and Population Pharmacokinetics of Sapropterin Dihydrochloride (Kuvan^®^) in Phenylketonuria (PKU) Patients <4 Years Old. (SPARK) (NCT01376908); - A Phase 3b Open-Label Study to Evaluate the Effect of Kuvan^®^ on Neurocognitive Function, Maintenance of Blood Phenylalanine Concentrations, Safety, and Population Pharmacokinetics in Young Children With Phenylketonuria (NCT00838435)
| In individuals with PKU responsive to BH4, what is the effect of BH4 plus diet compared with diet/standard care on outcomes including Phe control, Phe tolerance, cognitive outcomes (IQ and executive function), quality of life, liberalization of diet, family functioning, and harms of treatment over the long term (>2 years)? | - PKUDOS: Phenylketonuria (PKU) Demographic, Outcomes, and Safety Registry (NCT00778206); - Kuvan^®^ Adult Maternal Pediatric European Registry (KAMPER): Observational Study on the Long Term Safety of Kuvan^®^ Treatment in Patients With Hyperphenylalaninemia (HPA) Due to Phenylketonuria (PKU) or BH4 Deficiency (NCT01016392)
| What characteristics of the individual or family moderate responsiveness to BH4 in individuals with PKU? | - PKUDOS: Phenylketonuria (PKU) Demographic, Outcomes, and Safety Registry (NCT00778206); - Kuvan^®^ Adult Maternal Pediatric European Registry (KAMPER): Observational Study on the Long Term Safety of Kuvan^®^ Treatment in Patients With Hyperphenylalaninemia (HPA) Due to Phenylketonuria (PKU) or BH4 Deficiency (NCT01016392)
| What is the comparative effectiveness of BH4 in addition to diet, relative to diet alone, to reduce behavioral and psychological comorbidities in individuals with PKU? | - PKUDOS: Phenylketonuria (PKU) Demographic, Outcomes, and Safety Registry (NCT00778206); - Kuvan^®^ Adult Maternal Pediatric European Registry (KAMPER): Observational Study on the Long Term Safety of Kuvan^®^ Treatment in Patients With Hyperphenylalaninemia (HPA) Due to Phenylketonuria (PKU) or BH4 Deficiency (NCT01016392); - A Double-blind, Placebo-controlled, Randomized Study to Evaluate the Safety and Therapeutic Effects of Sapropterin Dihydrochloride on Neuropsychiatric Symptoms in Subjects With Phenylketonuria(NCT01114737)
| What characteristics of the individual, including disease severity, or characteristics of the family are associated with early vs. late initial response to BH4? | None identified
| In individuals with PKU not currently adherent to diet or receiving treatment for PKU, what are the effects of BH4 in promoting return to care? * | None identified
| How does treatment with BH4 modify other care processes, including the transition to care as an adult? * | None identified
3. What is the comparative effectiveness of BH4 with dietary intervention versus dietary intervention alone in pregnant women with PKU for affecting outcomes in their infants, including prevention of neurological impairment, microcephaly, and cardiac defects? | In pregnant women with PKU, what is the effect of BH4 plus diet compared with placebo plus diet/standard care on Phe control, cognitive outcomes (IQ and measures of executive function), QOL, liberalization of diet, and pregnancy outcomes? | - PKUDOS: Phenylketonuria (PKU) Demographic, Outcomes, and Safety Registry (NCT00778206); - Kuvan^®^ Adult Maternal Pediatric European Registry (KAMPER): Observational Study on the Long Term Safety of Kuvan^®^ Treatment in Patients With Hyperphenylalaninemia (HPA) Due to Phenylketonuria (PKU) or BH4 Deficiency (NCT01016392)
| What harms to the mother and offspring are associated with BH4 use in pregnant women with PKU? | - PKUDOS: Phenylketonuria (PKU) Demographic, Outcomes, and Safety Registry (NCT00778206); - Kuvan^®^ Adult Maternal Pediatric European Registry (KAMPER): Observational Study on the Long Term Safety of Kuvan^®^ Treatment in Patients With Hyperphenylalaninemia (HPA) Due to Phenylketonuria (PKU) or BH4 Deficiency (NCT01016392)
4. What is the comparative effectiveness of LNAAs with dietary intervention versus dietary intervention alone for affecting outcomes including measures of cognition (including executive function), quality of life, and nutritional status? | In individuals with PKU, what are the long-term effects (>6 months) of LNAAs on cognitive outcomes (IQ and executive function), quality of life, and liberalization of diet and harms of LNAAs? | - Effects of short term increase of phenylalanine levels on neuropsychological functions and well-being in adults with phenylketonuria: the “diet for life” study- supplement of amino acids (NTR1056)
| What harms are associated with LNAA use in individuals with PKU? | - Effects of short term increase of phenylalanine levels on neuropsychological functions and well-being in adults with phenylketonuria: the “diet for life” study- supplement of amino acids (NTR1056)
| What is the effectiveness of spectroscopy or other imaging techniques in assessing the effects of LNAAs on neurotransmission of Phe?^*^ | None identified
| What CNS biomarkers are effective for assessing the effects of LNAAs on the brain in individuals with PKU?^*^ | None identified
| In individuals with PKU not currently adherent to diet or receiving treatment for PKU, what are the effects of LNAAs in promoting return to care?^*^ | None identified
| How does treatment with LNAAs modify other care processes?^*^ | None identified
| How can the effects of LNAAs be measured and when should measurement occur?^*^ | None identified
| What methods are effective for measuring brain amino acid absorption?^*^ | None identified
7. What is the evidence for the effectiveness of the addition of BH4 or LNAAs to dietary intervention for affecting outcomes in subgroups of patients? | What are short-term effects of BH4 on outcomes including Phe control, Phe tolerance, cognitive outcomes (IQ and executive function), quality of life, and liberalization of diet, and harms of BH4 in specific subgroups (defined by age, dietary control, disease type)? | - PKUDOS: Phenylketonuria (PKU) Demographic, Outcomes, and Safety Registry (NCT00778206); - Kuvan^®^ Adult Maternal Pediatric European Registry (KAMPER): Observational Study on the Long Term Safety of Kuvan^®^ Treatment in Patients With Hyperphenylalaninemia (HPA) Due to Phenylketonuria (PKU) or BH4 Deficiency (NCT01016392); - Effects of Sapropterin on Brain and Cognition in Individuals With Phenylketonuria (NCT00730080); - Evaluation of Behavior, Executive Function, Neurotransmitter Function and Genomic Expression in PKU “Nonresponders” to Kuvan(NCT01274026); - Treatment of hyperphenylalaninemia with Sapropterin dihydrochloride (tetrahydrobiopterin, 6R-BH4) and its influence on the amino acids and fatty acids patterns from childhood to adulthood, a Phase IV, longitudinal, unblinded, controlled, single-centre, retrospective and prospective clinical study(ISRCTN77098312)
Overall / Foundational Questions | Among individuals with PKU using pharmacologic therapy, are supportive adherence models effective in increasing adherence? | None identified
Overall / Foundational Questions | Do interventions intended to increase adherence to diet or drug treatment in individuals with PKU lead to improved short-term and long-term cognitive outcomes? | None identified
Overall / Foundational Questions | Among effective adherence support systems, have individual components been shown to drive effectiveness? | None identified
Overall / Foundational Questions | Are promotion of adherence and related positive outcomes that occur over the long term modified by important factors that include developmental stage of the individual, age, family factors, Phe level, historical adherence, and type of PKU? | None identified
Overall / Foundational Questions | What are the pharmacokinetic, pharmacodynamic, and pharmacogenomic factors associated with treatment response in individuals with PKU? | None identified
Overall / Foundational Questions | Are passive registries as effective as ongoing cohort studies for collecting adequate data to assess long-term effectiveness of adjuvant therapies? | - PKUDOS: Phenylketonuria (PKU) Demographic, Outcomes, and Safety Registry (NCT00778206); - Kuvan^®^ Adult Maternal Pediatric European Registry (KAMPER): Observational Study on the Long Term Safety of Kuvan^®^ Treatment in Patients With Hyperphenylalaninemia (HPA) Due to Phenylketonuria (PKU) or BH4 Deficiency (NCT01016392)
Overall / Foundational Questions | In addition to blood Phe, what measures provide valid assessments of dietary control in individuals with PKU? | - PKUDOS: Phenylketonuria (PKU) Demographic, Outcomes, and Safety Registry (NCT00778206); - Kuvan^®^ Adult Maternal Pediatric European Registry (KAMPER): Observational Study on the Long Term Safety of Kuvan^®^ Treatment in Patients With Hyperphenylalaninemia (HPA) Due to Phenylketonuria (PKU) or BH4 Deficiency (NCT01016392)
Overall / Foundational Questions | What are the components of an effective system of care for individuals with PKU? | None identified
Overall / Foundational Questions | What treatment-related factors at different ages are the greatest source of concern to families / caregivers? | - 5-year Follow-up of the Comparison of Life and Physical Health in Adult Patients With PKU and Healthy Age Matched Controls (NCT01096758)
Overall / Foundational Questions | In individuals with PKU, what timing of Phe monitoring is optimal for fine tuning diet and treatment? | - The effects of online availability of individual phenylalanine levels to patients with phenylketonuria (NTR1171)
Overall / Foundational Questions | What medical supports can bring individuals with PKU back to treatment and/or dietary adherence?^*^ | None identified
Overall / Foundational Questions | Which biomarkers are effective for demonstrating response to treatment or therapeutic efficacy in PKU? * | None identified
Overall / Foundational Questions | What is the utility of the plasma Phe/Tyrosine ratio compared with plasma Phe level as a measure of Phe control in PKU? * | None identified
Overall / Foundational Questions | Are medical foods adequate to overcome vitamin and mineral deficiencies over the lifetime in individuals with PKU? * | None identified
Overall / Foundational Questions | What biomarkers are valid for understanding the effects of vitamin and mineral deficiencies in PKU? * | None identified
Overall / Foundational Questions | What is an appropriate study duration for understanding cognitive and other effects in individuals with PKU? * | None identified
Overall / Foundational Questions | How can nutritional status be effectively measured in PKU? * | None identified
Overall / Foundational Questions | What is the role of functional neuroimaging in PKU? * | None identified
Overall / Foundational Questions | What is the role of combination therapy in PKU? * | None identified
Overall / Foundational Questions | How can the effectiveness of combination therapies be measured? * | None identified
Overall / Foundational Questions | How should registry data collection be modified to allow for collection of efficacy data? * | None identified

* Questions derived from stakeholder calls

Abbreviations: ADHD=attention deficit hyperactivity disorder; BH4=sapropterin dihydrochloride; IQ=intelligence quotient; LNAA=large neutral amino acids; Phe=phenylalanine; PKU=phenylketonuria; QOL=quality of life

Stakeholders also identified several research questions that fell out of the scope of the current project’s Key Questions and analytic framework. Therefore, these questions could not be included in the prioritization process. They are, however, important questions to the field, and therefore we list them here:

- What is the effectiveness of medications to treat ADHD, anxiety, depression, and other mental health comorbidities in individuals with PKU?
- What methods are effective for identifying and reaching individuals with PKU not currently under care?
- What is the natural history of PKU?
- How does defining responsiveness in terms of Phe level or Phe tolerance or in terms of cognition or other long-term outcomes affect care for individuals with PKU?

We also identified a number of nonresearch issues/recommendations in the report and expanded with stakeholder feedback; we include these issues in the Discussion section of the report. We did not ask stakeholders to prioritize these nonresearch issues but note that further exploration would benefit our understanding of PKU.

### Round One Prioritization

As noted, we presented the expanded list of research needs in Table 5 to stakeholders in an initial survey (round one survey). We requested that stakeholders review EHC prioritization criteria and then assign a number of points to each question to indicate priority. Eight of nine stakeholders completed the survey.

Table 5 Questions indentified as high priority in round one survey

Treatment-Oriented Questions
Do interventions intended to increase adherence to diet or drug treatment in individuals with PKU lead to improved short-term and long-term cognitive outcomes?
Are promotion of adherence and related positive outcomes that occur over the long term modified by important factors that include developmental stage of the individual, age, family factors, Phe level, historical adherence, and type of PKU?
In children ≤4 years old with PKU, what is the effect of BH4 plus diet compared with placebo plus diet/standard care on Phe control, cognitive outcomes (IQ and measures of executive function), QOL, liberalization of diet, and growth and development?
In individuals with PKU not currently adherent to diet or receiving treatment for PKU, what are the effects of BH4 in promoting return to care?
In individuals with PKU responsive to BH4, what is the effect of BH4 plus diet compared with diet/standard care on outcomes including Phe control, Phe tolerance, cognitive outcomes (IQ and executive function), quality of life, liberalization of diet, family functioning, and harms of treatment over the long term (>2 years)?
In individuals with PKU, what are the long-term effects (>6 months) of LNAAs on cognitive outcomes (IQ and executive function), quality of life, and liberalization of diet and harms of LNAAs?
In pregnant women with PKU, what is the effect of BH4 plus diet compared with placebo plus diet/standard care on Phe control, cognitive outcomes (IQ and measures of executive function), QOL, liberalization of diet, and pregnancy outcomes?
What are short-term effects of BH4 on outcomes including Phe control, Phe tolerance, cognitive outcomes (IQ and executive function), quality of life, and liberalization of diet, and harms of BH4 in specific subgroups (defined by age, dietary control, disease type)?
What are the components of an effective system of care for individuals with PKU?
What characteristics of the individual, including disease severity, or characteristics of the family are associated with early vs. late initial response to BH4?
What harms are associated with LNAA use in individuals with PKU?
What is the comparative effectiveness of BH4 in addition to diet, relative to diet alone, to reduce behavioral and psychological comorbidities in individuals with PKU?
What medical supports can bring individuals with PKU back to treatment and/or dietary adherence?
Methodologic-Oriented/Other Questions
How can the effectiveness of combination therapies be measured?
How should registry data collection be modified to allow for collection of efficacy data?
In addition to blood Phe, what measures provide valid assessments of dietary control in individuals with PKU?
To what degree do measures of executive function vary with cognition, in the context of varying levels of Phe?
To what degree does Phe level affect domains of social and emotional functioning in PKU?
To what extent are poor cognitive outcomes related to dietary deficiencies compared with Phe levels?
What biomarkers are valid for understanding the effects of vitamin and mineral deficiencies in PKU?
What is the effectiveness of spectroscopy or other imaging techniques in assessing the effects of LNAAs on neurotransmission of Phe?
What is the relationship between clinical measures of executive function and “real world”/adaptive functioning?
What is the validity, reliability, and responsiveness to change of existing tools for measuring executive function in individuals with PKU?
What methods are effective for measuring brain amino acid absorption?
When measuring executive function in individuals with PKU, when and how frequently should these measures be assessed?
Which domains of executive function (e.g., planning, inhibitory control) are most sensitive to changes in Phe in individuals with PKU?
Which measures, including executive function and affective disorder screens, are shown to be associated with changes in “real world”/adaptive functioning related to Phe level in individuals with PKU?

Abbreviations: BH4=sapropterin dihydrochloride; IQ=intelligence quotient; LNAA=large neutral amino acids; Phe=phenylalanine; QOL=quality of life; PKU=phenylketonuria

Table 5 lists the highest priority questions (questions scoring at least 5 points) identified via the round one survey. We organized questions broadly by area of focus (methodologic/other or treatment) and present them by category in no particular order.

### Final Prioritization

In our round two/final survey we requested that stakeholders score each of the 27 high-priority needs (Table 5) on each of the following EHC selection criteria4 using a 1 (low) to 5 (high) point scale:

- Potential for significant health impact
- Potential to reduce variation in clinical practices
- Potential for significant economic impact
- Potential risk from inaction
- Potential to address inequities
- Potential to allow assessment of ethical, legal, social issues pertaining to the condition
- Potential for new knowledge

Eight of nine stakeholders completed the survey. We tallied the scores for each need/question on each criterion to determine an overall score and divided the questions by range of scores into top, middle, and lower tiers (presented in no particular order within each tier in Table 8); we combined and clarified two treatment questions related to adherence supports into one as one question was effectively a subquestion addressing modifiers of adherence program effects. Thus, six needs/questions comprise the top tier/highest priority treatment-related needs.

Table 8 Middle and lower priority research questions

Type of Question | Question | Tier
Methodologic | To what degree do measures of executive function vary with cognition, in the context of varying levels of Phe? | Middle
Methodologic | To what degree does Phe level affect domains of social and emotional functioning in PKU? | Middle
Methodologic | What methods are effective for measuring brain amino acid absorption? | Middle
Methodologic | When measuring executive function in individuals with PKU, when and how frequently should these measures be assessed? | Middle
Methodologic | Which measures, including executive function and affective disorder screens, are shown to be associated with to changes in cognitive outcomes related to Phe level in individuals with PKU? | Middle
Methodologic | What is the effectiveness of spectroscopy or other imaging techniques in assessing the effects of LNAAs on neurotransmission of Phe? | Lower
Methodologic | What is the relationship between clinical measures of executive function and "real world"/ adaptive functioning? | Lower
Methodologic | What is the validity, reliability, and responsiveness to change of existing tools for measuring executive function in individuals with PKU? | Lower
Methodologic | Which domains of executive function (e.g., planning, inhibitory control) are most sensitive to changes in Phe in individuals with PKU? | Lower
Treatment | In children ≥4 years old with PKU, what is the effect of BH4 plus diet compared with placebo plus diet/standard care on Phe control, cognitive outcomes (IQ and measures of executive function), QOL, liberalization of diet, and growth and development? | Middle
Treatment | In individuals with PKU responsive to BH4 plus diet compared with diet/standard care on outcomes including Phe control, Phe tolerance, cognitive outcomes (IQ and executive function), quality of life, liberalization of diet, family functioning, and harms of treatment over the long term (>2years)? | Middle
Treatment | In individuals with PKU, what are the long-term effects (>6months) of LNAAs on cognitive outcomes (IQ and executive function), quality of life, and liberalization of diet and harms of LNAAs? | Middle
Treatment | What are short-term effects of BH4 on outcomes including Phe control, Phe tolerance cognitive outcomes (IQ and executive function), quality of life, liberalization of diet, and harms of BH4 in specific subgroups (defined by age, dietary control, disease type)? | Lower
Treatment | What characteristics of the individual, including disease severity, or characteristics of the family are associated with early vs. late initial response to BH4? | Lower
Treatment | What harms are associated with LNAA use in individuals with PKU? | Lower

Abbreviations: BH4=sapropterin dihydrochloride; IQ=intelligence quotient; LNAAs=large neutral amino acids; Phe=phenylalanine; PKU=phenylketonuria; QOL=quality of life

The results are presented below in two sections: first, the top-tier methodologic questions (Table 6), followed by those that received lower priority scores, and second, the top tier treatment-related questions (Table 7), followed by lower priority treatment questions.

Table 6 Highest priority methodologic and other questions

Question/Need | Tier
How can the effectiveness of combination therapies be measured? | Top
How should registry data collection be modified to allow for collection of efficacy data? | Top
In addition to blood Phe, what measures provide valid assessments of dietary control in individuals with PKU? | Top
To what extent are poor cognitive outcomes related to dietary deficiencies versus Phe levels? | Top
What biomarkers are valid for understanding the effects of vitamin and mineral deficiencies in PKU? | Top

Abbreviations: Phe=phenylalanine; PKU=phenylketonuria

Table 7 Highest priority treatment-related research questions, PICOTS elements, and potential study designs

Question/Need | Tier | Population | Intervention | Comparator | Outcomes | Timing | Setting | Potential Study Designs^*^
Do interventions intended to increase adherence to diet or drug treatment in individuals with PKU lead to improved short-term and long-term cognitive outcomes? Are promotion of adherence and related positive outcomes that occur over the long term modified by important factors that include developmental stage of the individual, age, family factors, Phe level, historical adherence, and type of PKU? | Top | Individuals with PKU | Adherence models, including social supports, electronic /online tools, print-based programs | Usual care without specific adherence support | Phe control, adherence, IQ, executive function, QOL | >6 months (ideally 12–24 months) | Clinic and community | RCT, prospective cohort
In pregnant women with PKU, what is the effect of BH4 plus diet compared with placebo plus diet/standard care on Phe control, cognitive outcomes (IQ and measures of executive function), QOL, liberalization of diet, and pregnancy outcomes? | Top | Pregnant women with PKU | BH4+diet | Placebo+ diet | Maternal outcomes: Phe control, QOL, liberalization of diet, pregnancy outcomes Child outcomes: Cognitive outcomes (IQ and measures of executive function), QOL, growth and development | >5 years | Obstetrical care setting | Prospective cohort, Registry studies
What are the components of an effective system of care for individuals with PKU? | Top | Individuals with PKU | System of care | Usual care | Phe control, patient satisfaction, retention in care, QOL | >6 months | Community care, clinical care | RCT, time series, stepped wedge
What is the comparative effectiveness of BH4 in addition to diet, relative to diet alone, to reduce behavioral and psychological comorbidities in individuals with PKU? | Top | Individuals with PKU | BH4+diet | Diet | Changes in measures of behavioral and psychological comorbidities (e.g., ADHD, depression, anxiety) | -- | Clinical care | RCTs, prospective cohort studies
In individuals with PKU not currently adherent to diet or receiving treatment for PKU, what are the effects of BH4 in promoting return to care? | Top | Individuals with PKU not adherent to diet or other treatment | Availability of BH4 | -- | Phe control, patient satisfaction, retention in care, QOL | -- | Community and clinic | Pre-post designs, stepped wedge
What medical supports can bring individuals with PKU back to treatment and/or dietary adherence? | Top | Individuals with PKU not adherent to treatment | Systems of health communication, education and adherence support directed to individuals not in treatment | -- | Rate of return to treatment, continuation of treatment for a designated period of time. For women trying to become pregnant, ability to establish Phe control prior to conception. | -- | Combination of clinic and community | Pre-post designs, stepped wedge

* See glossary of study designs at end of report

Abbreviations: ADHD=attention deficit hyperactivity disorder; BH4=sapropterin dihydrochloride; IQ=intelligence quotient; LNAAs=large neutral amino acids; Phe=phenylalanine; PKU=phenylketonuria; QOL=quality of life; RCT=randomized controlled trial

Of note, the scores were all very close, and no set of recommended studies should be considered low priority. The rating provides a relative measure; all of the research questions are important, but a subset comprises a priority set that should be addressed first. We broke down top tier treatment-related questions into PICOTS elements (Table 7). As methods-related questions typically do not involve effectiveness outcomes, we did not delineate PICOTS.

### Highest Priority Research Agenda

The questions below are those that were prioritized into the top tier of the potential research questions. We have expanded on specific issues that might warrant consideration by investigators wishing to study any of the highest priority research questions. Clearly, across the board, studies should be rigorous and include appropriate comparison groups. They should be adequately powered to assess effects, and followup should continue for an adequate period of time so as not to limit measurement to immediate or short-term outcomes. We outline specific considerations for the top tier of methodologic questions and for the top tier intervention research questions below.

Many, if not most, individuals with PKU are likely to be treated with combination approaches, and methods for designing studies that assess the effectiveness of different combinations, rather than individual treatments, should be developed and validated. The question of whether or how registry data can support this and other types of effectiveness research warrants consideration by the PKU community.

Three primary measurement issues reached top priority level. First, there is an urgent need to identify approaches beyond blood Phe, which cannot be assessed immediately, for capturing the degree to which individuals are maintaining dietary control. This information is critical for guiding treatment, and to the degree that it is possible the effects of dietary deficiencies themselves on cognitive outcomes should be disaggregated from the effects of increasing Phe so that future studies can account for any potential effect of nutrition that may confound studies focused on Phe. Finally, related to this question, is a need for more research identifying biomarkers that can identify vitamin and mineral deficiencies.

The intervention research questions that were prioritized into the top tier are presented in Table 7. Where appropriate we specify design-related issues as identified by the EPC team for investigators to consider. We also identify and describe methodologic challenges inherent in studying these questions that will warrant attention by the investigators who choose to pursue them in the Discussion chapter.

### Middle and Lower Priority Research Agenda

None of the research questions identified through this process was considered unimportant, and certainly, this is a field with substantial room for research growth. The questions listed in Table 8 might be considered second tier in terms of immediacy and need for answers, but they are, nonetheless important. Our focus for this project is on identifying a highest priority subset for immediate action, so we do not discuss the questions in this section but provide them for use by investigators and funders in the field. They also provide insight for policy makers into areas that are currently lacking in definitive, research-based evidence.