# References

1 Sarkissian CN, Gámez A, Scriver CR. What we know that could influence future treatment of phenylketonuria. J Inherit Metab Dis. Feb. 2009;32(1):3-9. [pmid: 18668342].
2 Matalon R, Michals-Matalon K, Bhatia G, et al. Large neutral amino acids in the treatment of phenylketonuria (PKU). J Inherit Metab Dis. Dec. 2006;29(6):732-8. [pmid: 16988900].
3 Agency for Healthcare Research and Quality. Future Research Needs Projects. Available at http://effectivehealthcare.ahrq.gov/index.cfm/search-for-guides-reviews-and-reports/?pageaction=displayproduct&productid=521. Accessed 3 July 2012.
4 Agency for Healthcare Research and Quality. Prioritization Criteria Methodology for Future Research Needs Proposals Within the Effective Health Care Program. Available at http://www.effectivehealthcare.ahrq.gov/index.cfm/search-for-guides-reviews-and-reports/?productid=964&pageaction=displayproduct. Accessed 3 July 2012.
5 Feillet F, MacDonald A, Hartung D, et al. Outcomes beyond phenylalanine: An international perspective. Mol Genet Metab. 2009;99:S79-S85. [pmid: 20123476].
6 Brumm VL, Bilder D, Waisbren SE. Psychiatric symptoms and disorders in phenylketonuria. Mol Genet Metab. Suppl 1. 2010;99:S59-63. [pmid: 20123472].
7 National Institutes of Health. Consensus Development Conference Statement: phenylketonuria: screening and management, October 16–18, 2000. Pediatrics. Oct. 2001;108(4):972-82. [pmid: 11581453].
8 Giovannini M, Verduci E, Salvatici E, et al. Phenylketonuria: Dietary and therapeutic challenges. J Inherit Metab Dis. Apr. 2007;30(2):145-52. [pmid: 17347911].
9 Koch R, Burton B, Hoganson G, et al. Phenylketonuria in adulthood: a collaborative study. J Inherit Metab Dis. Sep. 2002;25(5):333-46. [pmid: 12408183].
10 Somaraju UR, Merrin M. Sapropterin dihydrochloride for phenylketonuria. Cochrane Database of Systematic Reviews. 2010;(6). Language: English. Entry Date: 20101029. Publication Type: journal article.
11 Hegge KA, Horning KK, Peitz GJ, et al. Sapropterin: a new therapeutic agent for phenylketonuria. Ann Pharmacother. Sep. 2009;43(9):1466-73. [pmid: 19654333].
12 BioMarin Pharmaceutical Inc. Kuvan (sapropterin dihydrochloride) tablets: prescribing information. Novato, CA. BioMarin Pharmaceutical Inc. 2007.
13 Lee P, Treacy EP, Crombez E, et al. Safety and efficacy of 22 weeks of treatment with sapropterin dihydrochloride in patients with phenylketonuria. Am J Med Genet A. Nov. 15. 2008;146A(22):2851-9. [pmid: 18932221].
14 Levy HL, Milanowski A, Chakrapani A, et al. Efficacy of sapropterin dihydrochloride (tetrahydrobiopterin, 6R-BH4) for reduction of phenylalanine concentration in patients with phenylketonuria: a phase III randomised placebo-controlled study. Lancet. Aug. 11. 2007;370(9586):504-10. [pmid: 17693179].
15 Trefz FK, Burton BK, Longo N, et al. Efficacy of sapropterin dihydrochloride in increasing phenylalanine tolerance in children with phenylketonuria: a phase III, randomized, double-blind, placebo-controlled study. J Pediatr. May. 2009;154(5):700-7. [pmid: 19261295].
16 Burton BK, Bausell H, Katz R, et al. Sapropterin therapy increases stability of blood phenylalanine levels in patients with BH4-responsive phenylketonuria (PKU). Mol Genet Metab. Oct–Nov. 2010;101(2–3):110-4. [pmid: 20638313].
17 Burlina A, Blau N. Effect of BH(4) supplementation on phenylalanine tolerance. J Inherit Metab Dis. Feb. 2009;32(1):40-5. [pmid: 19067227].
18 Vernon HJ, Koerner CB, Johnson MR, et al. Introduction of sapropterin dihydrochloride as standard of care in patients with phenylketonuria. Mol Genet Metab. Jul. 2010;100(3):229-33. [pmid: 20418136].
19 Lambruschini N, Perez-Duenas B, Vilaseca MA, et al. Clinical and nutritional evaluation of phenylketonuric patients on tetrahydrobiopterin monotherapy. Mol Genet Metab. Dec. Suppl 1. 2005;86:S54-60. [pmid: 16040265].
20 Burton BK, Nowacka M, Hennermann JB, et al. Safety of extended treatment with sapropterin dihydrochloride in patients with phenylketonuria: Results of a phase 3b study. Mol Genet Metab. Aug. 2011;103(4):315-22. [pmid: 21646032].
21 Trefz FK, Scheible D, Frauendienst-Egger G. Long-term follow-up of patients with phenylketonuria receiving tetrahydrobiopterin treatment. J Inherit Metab Dis. 2010. Mar. 9. [pmid: 20217238].
22 Humphrey M, Nation J, Francis I, et al. Effect of tetrahydrobiopterin on Phe/Tyr ratios and variation in Phe levels in tetrahydrobiopterin responsive PKU patients. Mol Genet Metab. Sep–Oct. 2011;104(1–2):89-92. [pmid: 21624843].
23 Schindeler S, Ghosh-Jerath S, Thompson S, et al. The effects of large neutral amino acid supplements in PKU: an MRS and neuropsychological study. Mol Genet Metab. May. 2007;91(1):48-54. [pmid: 17368065].
24 Matalon R, Michals-Matalon K, Bhatia G, et al. Double blind placebo control trial of large neutral amino acids in treatment of PKU: effect on blood phenylalanine. J Inherit Metab Dis. Apr. 2007;30(2):153-8. [pmid: 17334706].
25 RTI-UNC Evidence Based Practice Center. Prioritization Software. Chapel Hill, NC. RTI-UNC Evidence Based Practice Center.
26 Harris P, Taylor R, Thielk R, et al. Research electronic data capture (REDCap)—A metadata-driven methodology and workflow process for providing translational research informatics support. J Biomed Inform. Apr. 2009;42(2):377-81. [pmid: 18929686].
27 Koch R, Levy HL, Matalon R, et al. The international collaborative study of maternal phenylketonuria: status report 1994. Acta Paediatr Suppl. Dec. 1994;407:111-9. [pmid: 7766945].
28 Koch R, Levy HL, Matalon R, et al. The North American Collaborative Study of Maternal Phenylketonuria. Status report 1993. Am J Dis Child. Nov. 1993;147(11):1224-30. [pmid: 8237918].
29 Koch R, Levy H, Hanley W, et al. Outcome implications of the International Maternal Phenylketonuria Collaborative Study (MPKUCS): 1994. Eur J Pediatr. Jul. Suppl 1. 1996;155:S162-4. [pmid: 8828636].
30 Koch R, Hanley W, Levy H, et al. A preliminary report of the collaborative study of maternal phenylketonuria in the United States and Canada. J Inherit Metab Dis. 1990;13(4):641-50. [pmid: 2122127].
31 Koch R, Friedman E, Azen C, et al. The International Collaborative Study of Maternal Phenylketonuria: status report 1998. Eur J Pediatr. Oct. Suppl 2. 2000;159:S156-60. [pmid: 11043164].
32 Miller BD, Blau GM, Christopher OT, et al. Sustaining and expanding systems of care to provide mental health services for children, youth and families across America. Am J Community Psychol. Jun. 2012;49(3–4):566-79. [pmid: 22543719].
33 Whitson ML, Kaufman JS, Bernard S. Systems of Care and the prevention of mental health problems for children and their families: integrating counseling psychology and public health perspectives. Prev Couns Psychol. Nov. 1. 2009;3(1):3-9. [pmid: 21179396].
34 Whitson ML, Connell CM, Bernard S, et al. The impact of youth and family risk factors on service recommendations and delivery in a school-based system of care. J Behav Health Serv Res. Apr. 2011;38(2):146-58. [pmid: 20165927].
35 Giovannini M, Verduci E, Salvatici E, et al. Phenylketonuria: nutritional advances and challenges. Nutr Metab (Lond). 2012;9(1):7. [pmid: 22305125].