# Glossary of Study Designs

Pre-post design: Study designs that collect data before and after an intervention
Prospective cohort study: Research study that follows groups of individuals over time and compares them for a given outcome
Randomized controlled trial: Controlled clinical trial that assigns participants randomly to two or more groups
Registry studies: Studies that use data from registries of patient information, which typically collect data on patients with a given diagnosis or condition or undergoing specific procedures or treatments
Stepped wedge: Study design in which interventions are typically sequentially rolled out or staggered over a number of time periods
Time series: Study design employing measurement of data at successive time points at specific time intervals