# Executive Summary

## Background

Phenylketonuria (PKU) is a metabolic disorder in which an inability to properly metabolize the amino acid phenylalanine (Phe) leads to a buildup of Phe in the blood, causing neurotoxicity and resulting in intellectual disability, delayed speech, seizures and behavior abnormalities. PKU is typically diagnosed at birth following abnormal newborn screening results. With adherence to a Phe-restricted diet, poor outcomes can be mitigated. Nonetheless, management of PKU can be difficult and onerous for the patient and the family, leading to interest in identifying new ways of managing this lifelong condition.

The mainstay for treatment of PKU is a diet that restricts the intake of Phe to control the Phe concentration in the blood. In 2007 the United States Food and Drug Administration approved sapropterin dihydrochloride (Kuvan^®^, formerly known as Phenoptin) for the treatment of PKU under the stipulation that studies regarding the drug’s efficacy and long-term safety continue. Sapropterin dihydrochloride (hereafter, BH4) is presumed to work by enhancing residual enzyme activity present in some individuals with PKU. In addition to a Phe-restricted diet and BH4, another potential treatment for PKU is large neutral amino acids (LNAAs). In theory, LNAAs decrease the brain Phe concentration by competing with Phe for shared amino acid transporters to cross the blood-brain barrier.1,2

The Vanderbilt Evidence-based Practice Center completed an Agency for Healthcare Research and Quality (AHRQ)-funded systematic review of adjuvant treatments (BH4, LNAAs) for PKU (published February 2012). The report focused on Key Questions related to outcomes and harms of adjuvant treatment with BH4 and LNAAs in individuals with PKU, including pregnant women with PKU, and effects in subgroups (defined by demographic, clinical, genotypic, and adherence-related variables such as age, disease severity, genetic mutations, and dietary status). Key Questions also addressed evidence for optimal Phe levels for minimizing cognitive impairment.

Overall, evidence was graded as insufficient to moderate to address treatment-related questions. Dietary management remains the mainstay of treatment for PKU, and maintaining control over the lifetime is an appropriate goal. Nonetheless, there is potential to support patients in achieving their clinical goals and possibly liberalizing their diet with adjuvant therapy. BH4 has been shown in two RCTs and two open label trials to reduce Phe levels in some patients, with significantly greater reductions seen in treated versus placebo groups. Overall, harms associated with the drug were minor. To date, there are no data to directly establish the potential effects of BH4 on longer term clinically important outcomes, including cognition, executive function, and quality of life. Thus, while the strength of evidence is moderate for a large, positive effect of BH4 on reducing Phe levels over the short term in some groups of patients showing initial responsiveness, evidence for the effect of BH4 on longer term clinical outcomes is low, and based on indirect associations, including a meta-analysis of the relationship of Phe levels and IQ.

In theory, supplementation of a Phe-restricted diet with LNAAs might have a beneficial effect on cognition as LNAAs may competitively inhibit transportation of Phe through the blood-brain barrier, thereby offering protection by potentially decreasing brain Phe levels. However, there was insufficient evidence to suggest that LNAAs could be a viable treatment option for reducing Phe levels or increasing Phe tolerance.

Increasing Phe is clearly associated with decreased IQ, with a probability of IQ less than 85 exceeding the population probability (approximately 15 percent) at blood Phe over 400 μmol/L and leveling off at about 80 percent at 2000 μmol/L (moderate strength of evidence). This finding supports the typical target goal for blood Phe levels in individuals with PKU (120 to 360 μmol/L).

## Methods

Table A outlines the project’s methods, which were modified from those used in prior future research needs projects.3 Briefly, we used a multistep process to identify evidence gaps, beginning with culling gaps as reported in the Comparative Effectiveness Review (CER) and gaps relevant to adjuvant treatment raised during a National Institutes of Health State of the Science conference session devoted to future research needs in PKU. We framed gaps as Population-Intervention-Comparators-Outcomes-Timing-Setting (PICOTS) questions by CER Key Question or as foundational or methodologic research for which greater understanding would benefit PKU treatment. We also indicated where ongoing research may begin to address questions.

Table A Methods for developing future research needs

Approach to Evidence Gap Identification
1. Generate preliminary list of research gaps based on gaps noted in the CER
2. Form stakeholder workgroup with representatives from groups including patient/family/advocacy organizations, the provider community, the research community, and funding agencies
3. Locate ongoing trials and other funded research
4. Conduct conference call with stakeholders to refine initial list of evidence gaps
5. Review teleconference responses and refine list of research gaps related to adjuvant treatment for PKU
Approach to Prioritization and Stakeholder Engagement for Prioritization
6. Request that stakeholders prioritize research gaps
7. Cull list of prioritized gaps to top tier research needs based on stakeholder voting
8. Request that stakeholders assess top priority needs using modified EHC selection criteria
Approach to Research Question Development and Considerations for Potential Research Designs
9. Determine potential study designs to address final list of research needs
10. Develop research needs report
11. Request stakeholder input on the draft research needs report
12. Finalize research needs report

Abbreviations: CER=comparative effectiveness review; EHC=Effective Health Care Program; PKU=phenylketonuria

We then convened a group of stakeholders broadly representative of research, clinical care, patient/consumer, and funder perspectives to provide input on the list and add additional questions as necessary. We engaged stakeholders agreeing to participate in the project via an initial conference call to introduce the project and to add to the list of gaps identified from the report. This call was followed by an email message including the revised list of gaps and inviting stakeholders to edit or add questions as necessary.

We presented the expanded list of questions to stakeholders via a Web-based survey that asked stakeholders to allot a number of votes to each question to indicate priority. We asked stakeholders to consider the overall importance of the question for PKU research but did not prescribe specific criteria for prioritizing at this phase. We limited the number of votes available to roughly two-thirds of the number of questions identified to ensure that stakeholders selected high-priority issues. We then compiled votes across stakeholders and questions to determine the top tier of research needs. We considered questions scoring at least 5 points to comprise the top tier.

We sent a second Web-based survey to stakeholders asking them to prioritize the top tier needs, divided into treatment/intervention- and methods-related questions, using the following modified Effective Health Care (EHC) program selection criteria:4

- Potential for significant health impact
- Potential to reduce variation in clinical practices
- Potential for significant economic impact
- Potential risk from inaction.
- Potential to address inequities
- Potential to allow assessment of ethical, legal, social issues pertaining to the condition
- Potential for new knowledge.

Stakeholders ranked each question on each of the criteria using a 1- (low) to 5- (high) point scale. We tallied scores across each criterion to determine an overall score for each question and divided questions into top, middle, and lower tiers for both treatment- and methods-focused needs according to overall scores. We determined research considerations for each of the top tier treatment-related needs by considering factors including the availability of relevant data sets; alignment with the system of care for PKU; and recruitment issues in rare diseases.

## Results

### Stakeholders

Stakeholders broadly represented clinical, research, and advocacy perspectives in PKU. The panel comprised nine stakeholders, including a physician from a pharmaceutical company, an advocate who has children with PKU, representatives from government agencies that fund research on developmental disabilities, a dietician and nutritionist, clinical researchers with expertise in generics and metabolism, and experts in developmental medicine and in bioethics. We generated lists of potential stakeholders via a review of potential Technical Expert Panel members and key informants for the CER, review of investigators in studies included in the CER, review of advocacy and other agencies relevant to PKU, and through consultation with our Task Order Officer (TOO). Eight of nine stakeholders had participated in the National Institutes of Health (NIH) PKU Scientific Review Conference: State of the Science and Future Research Needs conference.

### Research Needs

Table B lists the combined list of research questions from the CER and those generated by stakeholders, broadly categorized into methodologic-related and treatment-related questions.

Table B Research needs identified in CER and by stakeholders

Methodologic/Other-Related Questions
Which domains of executive function (e.g., planning, inhibitory control) are most sensitive to changes in Phe in individuals with PKU?
Which measures, including executive function and affective disorder screens, are shown to be associated with changes in cognitive outcomes related to Phe level in individuals with PKU?
To what degree do measures of executive function vary with cognition, in the context of varying levels of Phe?
What is the validity, reliability, and responsiveness to change of existing tools for measuring executive function in individuals with PKU?
When measuring executive function in individuals with PKU, when and how frequently should these measures be assessed?
Which measures of ADHD are valid, sensitive, and reliable for use in individuals with PKU?
What are the clinical benefits and limitations of distinguishing attention-related symptoms due to elevated Phe levels vs. from non-PKU-related factors such as individual behavior?
To what degree does Phe level affect domains of social and emotional functioning in PKU?
What is the relationship between clinical measures of executive function and “real world”/adaptive functioning?
What are the effects of nutritional status on measures of executive function or emotion?
To what extent are poor cognitive outcomes related to dietary deficiencies compared with Phe levels?
What is the effectiveness of spectroscopy or other imaging techniques in assessing the effects of LNAAs on neurotransmission of Phe?
What CNS biomarkers are effective for assessing the effects of LNAAs on the brain in individuals with PKU?
What methods are effective for measuring brain amino acid absorption?
Are passive registries as effective as ongoing cohort studies for collecting adequate data to assess long-term effectiveness of adjuvant therapies?
In addition to blood Phe, what measures provide valid assessments of dietary control in individuals with PKU?
What are the components of an effective system of care for individuals with PKU?
What treatment-related factors at different ages are the greatest source of concern to families/caregivers?
In individuals with PKU, what timing of Phe monitoring is optimal for fine tuning diet and treatment?
What biomarkers are valid for understanding the effects of vitamin and mineral deficiencies in PKU?
What is an appropriate study duration for understanding cognitive and other effects in individuals with PKU?
How can nutritional status be effectively measured in PKU?
What is the role of functional neuroimaging in PKU?
How should registry data collection be modified to allow for collection of efficacy data?
Treatment-Related Questions
In children ≤4 years old with PKU, what is the effect of BH4 plus diet compared with placebo plus diet/standard care on Phe control, cognitive outcomes (IQ and measures of executive function), QOL, liberalization of diet, and growth and development?
In individuals with PKU responsive to BH4, what is the effect of BH4 plus diet compared with diet/standard care on outcomes including Phe control, Phe tolerance, cognitive outcomes (IQ and executive function), quality of life, liberalization of diet, family functioning, and harms of treatment over the long term (>2 years)?
What characteristics of the individual or family moderate responsiveness to BH4 in individuals with PKU?
What is the comparative effectiveness of BH4 in addition to diet, relative to diet alone, to reduce behavioral and psychological comorbidities in individuals with PKU?
What characteristics of the individual, including disease severity, or characteristics of the family are associated with early vs. late initial response to BH4?
In individuals with PKU not currently adherent to diet or receiving treatment for PKU, what are the effects of BH4 in promoting return to care?
How does treatment with BH4 modify other care processes, including the transition to care as an adult?
In pregnant women with PKU, what is the effect of BH4 plus diet compared with placebo plus diet/standard care on Phe control, cognitive outcomes (IQ and measures of executive function), QOL, liberalization of diet, and pregnancy outcomes?
What harms to the mother and offspring are associated with BH4 use in pregnant women with PKU?
In individuals with PKU, what are the long-term effects (>6 months) of LNAAs on cognitive outcomes (IQ and executive function), quality of life, and liberalization of diet and harms of LNAAs?
What harms are associated with LNAA use in individuals with PKU?
In individuals with PKU not currently adherent to diet or receiving treatment for PKU, what are the effects of LNAAs in promoting return to care?
How does treatment with LNAAs modify other care processes?
How can the effects of LNAAs be measured and when should measurement occur?
What are short-term effects of BH4 on outcomes including Phe control, Phe tolerance, cognitive outcomes (IQ and executive function), quality of life, and liberalization of diet, and harms of BH4 in specific subgroups (defined by age, dietary control, disease type)?
Among individuals with PKU using pharmacologic therapy, are supportive adherence models effective in increasing adherence?
Do interventions intended to increase adherence to diet or drug treatment in individuals with PKU lead to improved short-term and long-term cognitive outcomes?
Among effective adherence support systems, have individual components been shown to drive effectiveness?
Are promotion of adherence and related positive outcomes that occur over the long term modified by important factors that include developmental stage of the individual, age, family factors, Phe level, historical adherence, and type of PKU?
What are the pharmacokinetic, pharmacodynamic, and pharmacogenomic factors associated with treatment response in individuals with PKU?
What medical supports can bring individuals with PKU back to treatment and/or dietary adherence?
Which biomarkers are effective for demonstrating response to treatment or therapeutic efficacy in PKU?
What is the utility of the plasma Phe/Tyrosine ratio compared with plasma Phe level as a measure of Phe control in PKU?
Are medical foods adequate to overcome vitamin and mineral deficiencies over the lifetime in individuals with PKU?
What is the role of combination therapy in PKU?
How can the effectiveness of combination therapies be measured?

Abbreviations: ADHD=attention deficit hyperactivity disorder; BH4=sapropterin dihydrochloride; CER=comparative effectiveness review; CNS=central nervous system; IQ=intelligence quotient; LNAA=large neutral amino acid; QOL=quality of life; PKU=phenylketonuria

#### Round One Prioritization

In the first prioritization (round one) survey, stakeholders prioritized needs by allotting a limited number of points to the questions. Eight of nine stakeholders completed the survey. The highest priority questions (questions scoring at least 5 points, n=27/50 needs) identified via the round one survey are outlined in the full report.

#### Final Prioritization

We then asked stakeholders to rate each of the 27 high-priority questions, divided into the broad categories of methodologic-or treatment-focused, on the EHC criteria listed above. Eight of nine stakeholders completed the survey. Tables C and D list the highest priority questions (in alphabetical order within each category).

Table C Highest priority methodologic and other research questions

Question/Need | Tier
How can the effectiveness of combination therapies be measured? | Top
How should registry data collection be modified to allow for collection of efficacy data? | Top
In addition to blood Phe, what measures provide valid assessments of dietary control in individuals with PKU? | Top
To what extent are poor cognitive outcomes related to dietary deficiencies compared with Phe levels? | Top
What biomarkers are valid for understanding the effects of vitamin and mineral deficiencies in PKU? | Top

Abbreviations: Phe=phenylalanine; PKU=phenylketonuria

Table D Highest priority treatment-related research questions, PICOTS elements, and potential study designs

Question/Need | Tier | Population | Intervention | Comparator | Outcomes | Timing | Setting | Potential Study Designs^*^
Do interventions intended to increase adherence to diet or drug treatment in individuals with PKU lead to improved short-term and long-term cognitive outcomes? Are promotion of adherence and related positive outcomes that occur over the long term modified by important factors that include developmental stage of the individual, age, family factors, Phe level, historical adherence, and type of PKU? | Top | Individuals with PKU | Adherence models, including social supports, electronic/online tools, print-based programs | Usual care without specific adherence support | Phe control, adherence, IQ, executive function, QOL | >6 months (ideally 12–24 months) | Clinic and community | RCT, prospective cohort
In pregnant women with PKU, what is the effect of BH4 plus diet compared with placebo plus diet/standard care on Phe control, cognitive outcomes (IQ and measures of executive function), QOL, liberalization of diet, and pregnancy outcomes? | Top | Pregnant women with PKU | BH4+diet | Placebo+diet | Maternal outcomes: Phe control, QOL, liberalization of diet, pregnancy outcomes Child outcomes: Cognitive outcomes (IQ and measures of executive function), QOL, growth and development | >5 years | Obstetrical care setting | Prospective cohort, Registry studies
What are the components of an effective system of care for individuals with PKU? | Top | Individuals with PKU | System of care | Usual care | Phe control, patient satisfaction, retention in care, QOL | >6 months | Community care, clinical care | RCT, time series, stepped wedge
What is the comparative effectiveness of BH4 in addition to diet, relative to diet alone, to reduce behavioral and psychological comorbidities in individuals with PKU? | Top | Individuals with PKU | BH4+diet | Diet | Changes in measures of behavioral and psychological comorbidities (e.g., ADHD, depression, anxiety) | -- | Clinical care
In individuals with PKU not currently adherent to diet or receiving treatment for PKU, what are the effects of BH4 in promoting return to care? | Top | Individuals with PKU not adherent to diet or other treatment | Availability of BH4 | -- | Phe control, patient satisfaction, retention in care, QOL | -- | Community and clinic | Pre-post designs, stepped wedge
What medical supports can bring individuals with PKU back to treatment and/or dietary adherence? | Top | Individuals with PKU not adherent to treatment | Systems of health communication, education and adherence support directed to individuals not in treatment | -- | Rate of return to treatment, continuation of treatment for a designated period of time. For women trying to become pregnant, ability to establish Phe control prior to conception. | -- | Combination of clinica and community | Pre-post designs, stepped wedge

* See glossary of study designs at end of report

Abbreviations: ADHD=attention deficit hyperactivity disorder; BH4=sapropterin dihydrochloride; Phe=phenylalanine; PICOTS=population-intervention-comparator-outcomes-timing-setting; PKU=phenylketonuria; QOL=quality of life; RCT=randomized controlled trial

We broke down treatment-related questions into PICOTS elements and provide potential study designs as determined by the EPC team (Table D). The full report lists all questions by priority tier (top, middle, lower).

## Discussion

Research gaps in PKU are due in part to the rarity of the disease, and many fundamental questions remain unanswered. The research gaps and needs identified through both the initial review of the CER and the stakeholder process fell into two primary categories: those that were methodologic or foundational in nature and those that were directly related to treatment intervention (and thus fit more directly into the comparative effectiveness rubric). The methodologic work is necessary to undergird the study of interventions and the two types of priority efforts should be considered in tandem.

Measuring combinations of therapeutic approaches, rather than isolating individual treatments is challenging under any circumstances. With a rare disease, the numbers of individuals on any specific combination of therapies will be small, increasing the complexity and difficulty of demonstrating effectiveness. Furthermore, the current dependence on blood Phe as a measure of dietary control is far from ideal. Because it requires laboratory time, it cannot be used to provide instant feedback that might support ongoing modifications to care. Efforts to develop technology to provide instant feedback on Phe have failed to date, but work is and should continue to provide families with the ability to obtain rapid feedback. One methodologic question focused on the need to understand how and under what circumstances registry data could be used for effectiveness research. The use of registries (as is currently being done with pregnant women) is likely to be a key part of improving care for PKU patients. Finally, the identification, prevention and role of dietary deficiencies in affecting the outcomes of patients with PKU was seen by the stakeholders as a worthy focus of future research.

Six intervention questions were designated as highest priority.

### Do interventions intended to increase adherence to diet or drug treatment in individuals with PKU lead to improved short-term and long-term cognitive outcomes? Are promotion of adherence and related positive outcomes that occur over the long term modified by important factors that include developmental stage of the individual, age, family factors, Phe level, historical adherence, and type of PKU?

Understanding how to support PKU patients in adherence to what may be an evolving care approach has potential implications for achieving effective Phe management and positive cognitive outcomes. Ideally, studies of adherence support will take the form of RCTs comparing adherence support to usual care/practice and comparing various approaches to adherence support, as well as prospective cohort studies with good assessment and analytic management of confounders. In particular, it would be helpful to know whether adherence approaches aimed at particular developmental stages are successful at instilling habits that persist, even as children age and move through other developmental stages. It may be that RCTs are best able to capture early gains, while well-conducted prospective cohort studies with advanced analytics can describe trajectories of effects as participants age and develop.

### In pregnant women with PKU, what is the effect of BH4 plus diet compared with placebo plus diet/standard care on Phe control, cognitive outcomes (IQ and measures of executive function), QOL, liberalization of diet, and pregnancy outcomes?

Studying the effects of BH4 in addition to diet among pregnant women is complicated by lack of safety data and ethical issues related to conducting randomized trials in this vulnerable population. Prospective cohort studies with good assessment and analytic management of confounders are rigorous approaches, and registry data will provide additional crucial information. In addition, measures of cognitive outcomes in children require long-term follow-up of both mothers and children. Cognitive outcomes are also driven by maternal IQ and must be controlled for analytically. Investigators should consider techniques to reduce bias and confounding in evaluation studies, including randomly selecting subjects, or including all subjects who received the intervention for assessment; retaining as many subjects in the evaluation over time as possible; having comparison groups that are equivalent at baseline on severity of PKU, age and maternal IQ; and using data analytic techniques that control for potential confounders

### What are the components of an effective system of care for individuals with PKU?

Research is needed that both describes and evaluates systems of care for individuals with PKU (including the medical home), and that rigorously assesses the contribution that individual components make to effective care. Particular challenges related to this research include the need to document carefully the intervention so that it could be replicated, to fully characterize patients and patient characteristics to assess their impact on effectiveness, to include enough variation to understand and measure the impact in the heterogeneous PKU population, and the use study designs that are able to produce causal estimates and usable measures of effect. Potential study designs would include RCTs, time series, stepped wedge designs and other designs used extensively in the field of quality improvement. Outcomes should include clinical outcomes as well as satisfaction and quality of life.

### What is the comparative effectiveness of BH4 in addition to diet, relative to diet alone, to reduce behavioral and psychological comorbidities in individuals with PKU?

RCTs are needed to examine the impact of BH4 and improved dietary management compared with diet alone on Phe control and whether improved Phe control affects the symptoms of ADHD, anxiety, depression or other psychological comorbidities. In addition to ongoing studies assessing behavioral effects of sapropterin in PKU, prospective cohort studies with good assessment and analytic management of confounders offer another rigorous approach. Studies evaluating behavioral and psychological outcomes will require comparison groups equivalent at baseline on severity of PKU, age, and type of psychological comorbidity as well as long-term followup. Reliable and valid assessment of behavioral and psychological outcomes is critical, and validated tests in PKU populations may not be available.

As the following questions are very closely related, we address them together.

### In individuals with PKU not currently adherent to diet or receiving treatment for PKU, what are the effects of BH4 in promoting return to care? What medical supports can bring individuals with PKU back to treatment and/or dietary adherence?

It is likely that most studies will take the form of pre- and postinvestigations, but these studies will be unable to assess what proportion of the nonadherent population returned to treatment. It may be possible to do comparative studies by implementing different approaches at different clinical sites, or using a stepped wedge design across sites. Such a study would assume that the numbers of nonadherent individuals in different geographic regions are essentially equivalent. This study design would have challenges related to cross-contamination, given the strong communication network within the PKU community at large. Thus, it will be important to work with individuals who do return to treatment to understand exactly what motivated them to return, and then to study carefully what elements of a support system help them to continue with their treatment.

Underpinning the ability to conduct the specific research described in this document is the need for investment in the type of infrastructure that supports the study of a rare disease. In particular, we recommend the establishment of a multi collaborator consortium that includes a public-private partnership. Collaborators in this consortium could develop or identify an agreed upon set of standardized data collection tools, especially for cognitive outcomes beyond IQ. Such a consortium should include guidelines for data sharing and comprehensive reporting, not only of intervention and outcome data, but of important, potentially confounding variables.

Stakeholders also emphasized the need for a health services research agenda on issues such as variation in care and in insurance access for medical foods. A related question is the ability to obtain care and treatment once children with PKU become adults. Finally, our stakeholders warned that the current workforce for caring for individuals with PKU is inadequate, and that the field needs to encourage and support training for a range of providers, including nonmetabolic nutritionists (for understanding exigencies of PKU) as well as psychiatrists and psychologists.

## Conclusions

The existing research gaps related to the use of adjunct pharmacologic therapy in PKU are both substantive and methodologic. Specific deficiencies range from the substantive need for more trials that include more individuals to methodologic gaps in our understanding of the longer term implications of intermediate outcomes. In both cases, research is fundamentally challenging because the disease is so rare, making accrual of adequate numbers of participants difficult, if not impossible, for specific studies. Our multistep process identified high-priority methodologic needs related to measurement of outcomes and dietary control and treatment-related needs including understanding adherence to treatment and an optimal system of care for affected individuals, the effects of BH4 on pregnant women, and effects on mental health and behavioral comorbidities. While ongoing research may begin to provide some answers, addressing research needs in PKU will require further long term, rigorously designed, comparative studies. Further research also requires expanding our foundation of understanding of critical aspects of the disease including its natural history, biologic mechanisms of disease, and ways to measure elevated Phe to better understand its effects on cognition. Stakeholders also emphasized that clinical decisionmaking will, by necessity be based on a range of factors, including the rarity of the disease, the devastating consequences of not treating and the association of treatment with quality of life and family functioning. Future comparative effectiveness research should include additional contextual data to support decisionmaking and increase its utility.