# Acknowledgments

We gratefully acknowledge the thoughtful input of the stakeholders who participated in this project and the work of the team of investigators who developed the original adjuvant therapies for PKU CER. We also wish to thank the RTI-UNC EPC for allowing us to use the prioritization software created by their team for our initial survey and the REDCap Consortium for the use of their survey software. We appreciate Ms. Shannon Brode’s assistance with using the RTI-UNC tool.