# Discussion

We used a multistep process adapted from prior AHRQ EPC future research needs projects to identify top tier research needs related to adjuvant pharmacologic therapies for PKU. Research gaps in PKU are due in part to the rarity of the disease, and many fundamental questions remain unanswered. The scope of the current project was limited by the scope of the original CER to research regarding the use of pharmacologic therapies in addition to dietary restriction to improve short and long-term outcomes. While this limitation can prove challenging in some future research needs processes, for this topic the large number of critical questions within the topic did not put excessive limitations on our process or the product.

In the first phase of the process, we developed a list of initial research gaps from the CER and invited stakeholders to add to or modify that initial list during two conference calls. We then invited stakeholders to review the list on their own time and to add any additional questions that they thought would be important to include. This snowballing process allowed us to develop a comprehensive list from which to identify highest priority areas. Providing stakeholders adequate opportunity to build this list increased its comprehensiveness and ensured that at the prioritization phase there were adequate choices amongst which to identify the highest priorities. Once this list was developed, stakeholders participated in a two-step prioritization exercise. In the first step they identified a high-priority set of questions from the list, culling the initial list of questions down to a high-priority tier of 27 questions. In the second step, they further prioritized these high-priority questions. We then divided questions by points allotted into top, middle and lower tier research needs, divided roughly by thirds.

The results of this process are presented in this manuscript, with a focus on those that were designated as highest priority in the final prioritization round. We discuss lessons learned from the process, then the high-priority research recommended by the stakeholders. The stakeholder process itself was facilitated by the integration of the original CER into a NIH Scientific Review Conference (PKU Scientific Review Conference: State of the Science and Future Research Needs), and we encourage further integration of efforts related to the conference. The CER report was presented at the conference, providing an opportunity for the team to achieve greater understanding of the research challenges in the field and for potential stakeholders to be educated on the AHRQ EPC program and the particular process of this topic. Even so, we did not get complete participation from the invited stakeholders, with eight invitees not responding to or declining our invitation. Most of the stakeholders (eight of nine individuals) who participated in the project had attended the NIH conference.

Once stakeholders were engaged, we held two conference calls in order to accommodate busy schedules. While it can be helpful to have all stakeholders on one call to facilitate a comprehensive conversation (i.e., with all viewpoints represented), we found that the smaller groups meant that individuals could each participate more and all members were actively engaged. There was substantial congruency in the information across the calls. We found the stakeholders were quickly responsive to requests for snowballing or prioritization on line, with all stakeholders completing all portions of the process. In part, we believe this reflects a strong commitment on the part of the stakeholders to raising the visibility of PKU as a priority area for research. A consistent theme at the conference and in our interactions with stakeholders was that this area of research is substantially underfunded and warrants attention, particularly in light of the potentially devastating effects of nontreatment.

The research gaps and needs identified through both the initial review of the CER and the stakeholder process fell into two primary categories: those that were methodologic or foundational in nature and those that were directly related to treatment intervention (and thus fit more directly into the comparative effectiveness rubric). Therefore, we have discussed the two types of research separately here. The methodologic work is necessary to undergird the study of interventions and the two types of priority efforts should be considered in tandem.

## Research Considerations: Methodologic and Treatment Questions

There were five methodologic issues identified as high priorities for immediate research attention:

- How can the effectiveness of combination therapies be measured?
- In addition to blood Phe, what measures provide valid assessments of dietary control in individuals with PKU?
- How should registry data collection be modified to allow for collection of efficacy data?
- To what extent are poor cognitive outcomes related to dietary deficiencies versus Phe levels?
- What biomarkers are valid for understanding the effects of vitamin and mineral deficiencies in PKU?

Two of these are clearly measurement issues. Measuring combinations of therapeutic approaches, rather than isolating individual treatments is challenging under any circumstances. With a rare disease, the numbers of individuals on any specific combination of therapies will be small, increasing the complexity and difficulty of demonstrating effectiveness. Furthermore, the current dependence on blood Phe as a measure of dietary control is far from ideal. Because it requires laboratory time, it cannot be used to provide instant feedback that might support ongoing modifications to care. Efforts to develop technology to provide instant feedback on Phe have failed to date, but work is and should continue to provide families with the ability to obtain rapid feedback. One methodologic question focused on the need to understand how and under what circumstances registry data could be used for effectiveness research. The PKU community is motivated to collect and analyze data that might support better understanding of both questions of natural history and treatment. The use of registries (as is currently being done with pregnant women) is likely to be a key part of improving our ability to properly care for PKU patients. Finally, the identification, prevention and role of dietary deficiencies in affecting the outcomes of patients with PKU was seen by the stakeholders as a worthy focus of future research. They noted particularly that some cognitive effects perceived to be associated with increased Phe could in fact be caused by dietary deficiencies. As such, understanding what vitamin and mineral deficiencies may occur, how to identify them and how they correspond to cognitive outcomes would be of benefit both for clinical care and to understand outcomes observed in effectiveness research.

Research on the use of BH4 as an adjuvant therapy in PKU management is relatively new and consists of small, tightly controlled multisite efficacy studies, two of which are RCTs. The greatest research need in this area is thus for larger studies that include adequate numbers of participants. Given the known difficulty of accruing large numbers of participants, however, researchers should also use existing data sets and, as recommended, use a consortium and multisite approach to gathering data. Ideally, studies will be conducted in both tightly controlled and nonadherent populations, and among different age groups, with appropriate design and power for subgroup analyses. Research should continue to include RCTs, but prospective cohort studies that may have the potential to provide additional effectiveness data—including outside of a controlled clinical setting—adherence and longer term evidence would also be helpful to support understanding of the role of BH4 in clinical care. Six specific treatment/intervention questions were designated as highest priority; we outline the questions and provide discussion on each below.

### Do interventions intended to increase adherence to diet or drug treatment in individuals with PKU lead to improved short-term and long-term cognitive outcomes? Are promotion of adherence and related positive outcomes that occur over the long term modified by important factors that include developmental stage of the individual, age, family factors, Phe level, historical adherence, and type of PKU?

Because of the life-long nature of PKU, treatment occurs over the life course, including dietary restriction, use of medical foods and formula, and pharmacologic therapy. Treatment effectiveness will be modified by the degree to which individuals are able to adhere to their prescribed course of treatment. Thus, understanding how to support patients with PKU in consistent and appropriate adherence to what may be an evolving care approach has potential implications for achieving effective Phe management and positive cognitive outcomes. Interventions to support adherence are likely to include social support in group or individual formats, online support that may or may not include tailored approaches, telephone and text reminder systems as well as print-based tools. Adherence support may take place in a clinical setting or in the community and may or may not be part of one’s clinical care.

Ideally, studies of adherence support will take the form of RCTs comparing adherence support to usual care/practice and comparing various approaches to adherence support, as well as prospective cohort studies with good assessment and analytic management of confounders. It is imperative that studies include comparison groups. Investigators will be challenged to include in their studies adequate numbers of participants to assess the potential modifiers of success listed above. In particular, it would be helpful to know whether adherence approaches aimed at particular developmental stages are successful at instilling habits that persist, even as children age and move through other developmental stages. Identifying an ideal developmental target would help in the development of effective materials and approaches. Furthermore, such studies will require long term follow up that is conducted in such a way that the effects of interventions provided at specific points can be isolated, regardless of future interventions. It may be that RCTs are best able to capture early gains, while well-conducted prospective cohort studies with advanced analytics can describe trajectories of effects as participants age and develop.

### In pregnant women with PKU, what is the effect of BH4 plus diet compared with placebo plus diet/standard care on Phe control, cognitive outcomes (IQ and measures of executive function), QOL, liberalization of diet, and pregnancy outcomes?

Elevated maternal Phe level during pregnancy is teratogenic. Abnormalities include intrauterine growth restriction, microcephaly, congenital heart defects, developmental delays, and intellectual disability in children born to women with poorly controlled PKU during pregnancy. The effects of uncontrolled maternal PKU occur regardless of whether the fetus has PKU. The Maternal PKU Collaborative Study, the largest study to prospectively follow women with PKU who were pregnant, followed 572 pregnancies with 412 live births from 1984 to 2002.^27–31^ Results of this important study demonstrated that the best observed neonatal outcomes occurred when strict control of maternal blood Phe (120–360 μmol/L) was initiated before pregnancy or by 8 weeks post conception. This level of strict compliance with a Phe-restricted diet during both preconception and periconception is challenging. It is complicated by potential nausea and vomiting during the first trimester that may limit adherence to a strict diet and result in poor maternal nutrition. However, identifying and educating women about the importance of adherence before conception is also difficult as most women do not realize they are pregnant until they have missed a period. Many young women with PKU have lost adherence to dietary control by late adolescence, dropped out of pediatric care and may not have transitioned to adult care settings, and if they do seek care from a PKU clinic it is often after 8 weeks of pregnancy. However, BH4 may provide an impetus for women to return to PKU care, thus providing access to family planning and preconception care, including management of Phe levels, early identification of pregnancies and better management in early pregnancy, when strict control is especially critical.

Studying the effects of BH4 in addition to diet among pregnant women is complicated by lack of safety data and ethical issues related to conducting randomized trials in this vulnerable population. Prospective cohort studies with good assessment and analytic management of confounders are a rigorous approach, and registry data will provide additional crucial information. In addition, measures of cognitive outcomes in children require long-term follow-up of both mothers and children. Cognitive outcomes are also driven by maternal IQ and must be controlled for analytically. Investigators should consider techniques to reduce bias and confounding in evaluation studies, including randomly selecting subjects, or including all subjects who received the intervention for assessment; retaining as many subjects in the evaluation over time as possible; having comparison groups that are equivalent at baseline on severity of PKU, age and maternal IQ; and using data analytic techniques that control for potential confounders

### What are the components of an effective system of care for individuals with PKU?

The system of care in place to support individuals with PKU includes a complex set of stakeholders in the health care system. “System of Care” is itself a specific approach and has been studied in the mental health field for a number of years.32–34 Care related to PKU requires participation by clinical experts in genetics, developmental pediatrics, nutrition, and psychology, and may also include support for health advocacy, attainment of insurance coverage, legal and social support as well as family education and support. Care and support that is coordinated may be more effective at helping PKU patients reach their individual goals related to Phe management, cognition and high quality of life, but specific systems of care are currently not described or evaluated in the scientific literature.

Research is needed that both describes and evaluates systems of care for individuals with PKU (including the medical home), and that rigorously assesses the contribution that individual components make to effective care. Particular challenges related to this research include the need to document carefully the intervention so that it could be replicated, to fully characterize patients and patient characteristics to assess their impact on effectiveness, to include enough variation to understand and measure the impact in the heterogeneous PKU population, and the use study designs that are able to produce causal estimates and usable measures of effect. Potential study designs would include RCTs, time series, stepped wedge designs and other designs used extensively in the field of quality improvement. Outcomes should include clinical outcomes as well as satisfaction and quality of life.

### What is the comparative effectiveness of BH4 in addition to diet, relative to diet alone, to reduce behavioral and psychological comorbidities in individuals with PKU?

In several studies, populations with PKU have been found to have higher prevalence rates of behavioral difficulties and other psychological comorbidities, including ADHD, anxiety, and depression, compared with the general population. Few studies have evaluated the relationship of these psychological outcomes to Phe control. Challenges include the difficulty distinguishing behaviors related to Phe control and intellectual status, socio-demographic factors, or underlying neurobiology. Studies have also been limited by small populations with large variations in behaviors scores, Phe levels, and IQ. Psychological comorbidities (e.g., ADHD) may overlap in neurobiologic mechanism, as populations with PKU and ADHD are both thought to have low levels of dopamine, especially in the prefrontal cortex, and this hypodopamine state has direct effect on behavior. Thus, if strict dietary management and BH4 improve Phe control and the symptoms of ADHD or other psychological outcomes are reduced, there may be no need for treatment (e.g., stimulant medications), but if symptoms are related to overlapping mechanisms, even with improved Phe control these symptoms may persist and require treatment.

There is a need for rigorously designed evaluation studies to evaluate the comparative effectiveness of BH4 in addition to diet on behavioral and psychological comorbidities. Ideally, RCTs are needed to examine the impact of BH4 and improved dietary management compared with diet alone on Phe control and whether improved Phe control impacts the symptoms of ADHD, anxiety, depression or other psychological comorbidities. Three studies are currently evaluating behavioral effects of sapropterin in PKU. One BioMarin-sponsored study is a US- and Canada-based RCT recruiting 200 individuals with PKU 12 years of age and older to evaluate the effect of BH4 compared with placebo on ADHD symptoms. The second is studying effects on behavior in 6- to 18-year old individuals (N=20) with PKU (sponsored by Washington University School of Medicine collaborating with BioMarin and the University of Missouri-Columbia, Northwestern University, and Oregon Health and Science University). The third study, from the University of Southern California collaborating with BioMarin, is evaluating behavior in 13 participants with PKU taking sapropterin.

Additionally, prospective cohort studies with good assessment and analytic management of confounders is another rigorous approach. It is imperative that studies include comparison groups. To reduce bias and confounding in evaluation studies, investigators should consider several techniques including randomly assigning participants to the intervention group; randomly selecting subjects, or including all subjects who received the intervention, for assessment; retaining as many subjects in the evaluation over time as possible; having comparison groups that are equivalent at baseline on severity of PKU, age-group, and type of psychological comorbidity; and using data analytic techniques that control for potential confounders (IQ, maternal IQ, etc).

These studies evaluating behavioral and psychological outcomes will require more long term followup. Reliable and valid assessment of behavioral and psychological outcomes is critical and validated tests in PKU populations may not be available.

As the following questions are very closely related, we address them together.

### In individuals with PKU not currently adherent to diet or receiving treatment for PKU, what are the effects of BH4 in promoting return to care? What medical supports can bring individuals with PKU back to treatment and/or dietary adherence?

A fundamental challenge in care for individuals with PKU is the high rate of nonadherence, particularly as individuals with PKU age through adolescence and into adulthood. With increasing data confirming that lifelong Phe management is ideal for all individuals, and essential for women who may become pregnant, clinicians face the challenge of bringing individuals back to treatment that they may have abandoned. 7–9,35 Restarting a restrictive diet can be unpleasant and difficult.

The question of how the medical system can encourage individuals to return to treatment crosses clinical, health behavior and health education lines, and warrants multidisciplinary research that reflects each of these fields. In addition to the promise of BH4, as in the research question above, the issue is to establish what type of education and health communication systems, combined with clinical diet training and adherence support, is most effective and leads to the highest rate of return to care.

Investigators wishing to study this question will be challenged first by a lack of an unequivocal denominator. It is unknown precisely how many individuals have ceased to be adherent to treatment. It is likely that most studies will take the form of pre- and postinvestigations, but these studies will be unable to assess what proportion of the nonadherent population returned to treatment. It may be possible to do comparative studies by implementing different approaches at different clinical sites, or using a stepped wedge design across sites, given that the sites treating where individuals with PKU are treated are well known and often collaborate on research. Such a study would assume that the numbers of nonadherent individuals in different geographic regions are essentially equivalent. This study design would have challenges related to cross-contamination, given the strong communication network within the PKU community at large. Thus, it will be very important to work with individuals who do return to treatment to understand exactly what motivated them to return, and then to study carefully what elements of a support system help them to continue with their treatment.

## Other Considerations

Underpinning the ability to conduct the specific research described in this document is the need for investment in the type of infrastructure that supports the study of a rare disease. Other rare conditions have benefited from an overall research agenda. To this end, we recommend that a multicollaborator process that includes a public-private partnership which could create a powerful tool for the future of PKU research in the form of implementing a longer term (perhaps 10-year) research agenda. Furthermore, because the metabolic centers that treat patients with PKU are identifiable, and because PKU patients are almost inevitably treated in such a center if they are receiving care, there is tremendous potential for development of a multicenter research consortium to comprehensively evaluate the complete system of care for individuals with PKU. Such a collaborative effort is necessary for a number of the potential research tracks described above, including describing systems of care, and supporting the expansion of registries. Collaborators in this consortium could also develop or identify an agreed upon set of standardized data collection tools, especially for cognitive outcomes beyond IQ. Such a consortium should include guidelines for data sharing and comprehensive reporting, not only of intervention and outcome data, but of important, potentially confounding variables.

Stakeholders also emphasized the need for a health services research agenda that might better document issues such as variation in care and in insurance access for medical foods. Given good evidence that Phe is ideally controlled across the lifespan, a related question is the ability to obtain care and treatment once children with PKU become adults.

Finally, our stakeholders warned us that the current workforce for caring for individuals with PKU is inadequate, and that the field very much needs to encourage and support training for a range of providers, including nonmetabolic nutritionists (for understanding exigencies of PKU) as well as psychiatrists and psychologists.