# Background

## Context

Phenylketonuria (PKU) is a metabolic disorder in which an inability to properly metabolize the amino acid phenylalanine (Phe) leads to a buildup of Phe in the blood, causing neurotoxicity and resulting in intellectual disability, delayed speech, seizures and behavior abnormalities. Individuals with PKU are also susceptible to other adverse outcomes, including impaired executive function, reduced processing speed, attention problems, impaired fine motor skills, and mental health concerns (such as anxiety and depression symptoms).5,6 PKU is typically diagnosed at birth following abnormal newborn screening results. With adherence to a Phe-restricted diet, poor outcomes can be mitigated. Nonetheless, management of PKU can be difficult and onerous for the patient and the family, leading to interest in identifying new ways of managing this lifelong condition. Further, questions remain as to the empirical basis for the selection of specific blood Phe levels as targets to reflect good dietary control.

The mainstay for treatment of PKU is a diet that restricts the intake of Phe to control the Phe concentration in the blood. In general, the usual treatment goal is a blood Phe level of 120 to 360 μmol/L. However, there is some variation in the target Phe level between clinics and across countries.7,8 In addition to the low-Phe diet, many patients take vitamins and minerals daily to replace the nutrients that are absent in their restricted diet.8 Historically, Phe levels were only monitored closely during the first 6 years of life (the “critical period”) because elevated Phe after that age was not believed to be detrimental. However, based on accumulated evidence over the last few decades, it is now standard of care to recommend strict adherence to a Phe-restricted diet and routine monitoring of Phe levels throughout life.7,9

In 2007 the United States Food and Drug Administration (FDA) approved sapropterin dihydrochloride (Kuvan^®^, formerly known as Phenoptin) for the treatment of PKU under the stipulation that studies regarding the drug’s efficacy and long-term safety continue. Sapropterin dihydrochloride (hereafter, BH4) is presumed to work by enhancing residual enzyme activity present in some individuals with PKU. Although treatment with BH4 would potentially allow a relaxation of the low-Phe diet, it is not intended to serve as a complete substitute for dietary intervention.10

In addition to a Phe-restricted diet and BH4, another potential treatment for PKU may be large neutral amino acids (LNAAs). LNAAs are considered nutritional supplements and are not subject to FDA approval. In theory, LNAAs decrease the brain Phe concentration by competing with Phe for shared amino acid transporters to cross the blood-brain barrier.1,2 When used in clinical practice, LNAAs generally are offered to individuals who are unable to maintain dietary adherence.

A Phe-restricted diet throughout life has been well established as the cornerstone of treatment for PKU by studies such as the PKU Collaborative Study.9 Yet PKU is a rare metabolic disease, and there are limited data on the best adjunct treatment in addition to diet for different ages. Although most clinics use a blood Phe level of 120 to 360 μmol/L as the goal treatment range, evidence is mixed on a specific optimal range for minimizing the clinical and cognitive effects of elevated blood Phe levels across different ages of individuals, including pregnant women. Furthermore, the efficacy, safety, and target populations for the concomitant use of BH4 or LNAAs with a Phe-restricted diet have not been established, and clinicians lack evidence-based support for when to prescribe BH4 or LNAAs and in which patients.

The implications of liberalizing the diet in those patients who do achieve blood Phe levels below treatment goals are currently unknown in terms of their effect on short- and long-term clinical and cognitive effects. Finally, the safety and efficacy of the use of BH4 and LNAAs in pregnant women and in children, including infants, are unknown.11,12 Further complicating clinical decisionmaking is the difficulty in studying such a rare disease. Not only is research challenging logistically, but little Federal funding is available to support such research. The availability and quality of research evidence is unlikely to reach the level of more common clinical conditions; nonetheless, we know with certainty that failure to treat this condition with a Phe-restricted diet with or without concomitant use of BH4 or LNAAs leads to very poor outcomes. Clinicians, patients, and their families must make the best decisions possible about what treatment avenues to pursue in the presence of uncertainty.

### Adjuvant Treatment for PKU Systematic Review

In 2010, the Vanderbilt Evidence-based Practice Center completed an Agency for Healthcare Research and Quality (AHRQ)-funded systematic review of adjuvant treatments (BH4, LNAAs) for PKU. The report focused on the following Key Questions related to adjuvant treatment:

Key Question 1a What is the evidence that any specific Phe levels are optimal for minimizing or avoiding cognitive impairment in individuals with PKU?
Key Question 1b What is the evidence that different target Phe levels are appropriate for minimizing or avoiding cognitive impairment for different age groups?
Key Question 2 What is the comparative effectiveness of BH4 with dietary intervention versus dietary intervention alone for affecting outcomes including measures of cognition (including executive function), quality of life, and nutritional status? Subgroups include the following:
  a. infants with PKU
  b. children ages 2 to 12 years old with PKU
  c. adolescents ages 13 to 21 years old with PKU
  d. adults ≥21 years old with PKU
Key Question 3 What is the comparative effectiveness of BH4 with dietary intervention versus dietary intervention alone in pregnant women with PKU for affecting outcomes in their infants, including prevention of neurological impairment, microcephaly, and cardiac defects?
Key Question 4 What is the comparative effectiveness of LNAAs with dietary intervention versus dietary intervention alone for affecting outcomes including measures of cognition (including executive function), quality of life, and nutritional status? Subgroups include the following:
  a. infants with PKU
  b. children ages 2 to 12 years old with PKU
  c. adolescents ages 13 to 21 years old with PKU
  d. adults ≥21 years old with PKU
Key Question 5 What is the comparative effectiveness of LNAAs with dietary intervention versus dietary intervention alone in pregnant women with PKU for affecting outcomes in their infants, including prevention of neurological impairment, microcephaly, and cardiac defects?
Key Question 6 What are the harms, including adverse events, associated with the use of BH4, LNAAs, and/or dietary intervention in individuals with PKU?
Key Question 7 What is the evidence for the effectiveness of the addition of BH4 or LNAAs to dietary intervention for affecting outcomes in subgroups of patients? The following are examples of potential defining characteristics of subgroups:
  - demographic
  - clinical
  - genotypic
  - adherence

### Key Findings of the Evidence Report

#### Phe Levels and Cognitive Outcomes

Seventeen studies were included in the meta-analysis, providing data on 432 individuals who ranged from age 2 to 34 years. The CER modeled the association of IQ less than 85 with blood Phe level, accounting for time of Phe measurement relative to cognitive testing, and whether or not the measurement occurred in the critical period (<6 years of age). Increasing Phe is clearly associated with decreased IQ, with a probability of IQ less than 85 exceeding the population probability (approximately 15 percent) at blood Phe over 400 μmol/L and leveling off at about 80 percent at 2000 μmol/L. This finding supports the typical target goal for blood Phe levels in individuals with PKU (120 to 360 μmol/L).

Studies of the association of blood Phe and executive function targeted many specific outcomes, precluding straightforward quantitative analysis of the data. Some studies clearly suggest that elevated Phe is likely associated with poorer outcomes but data are inconsistent across types of measures.

#### BH4

Ten studies evaluated the effects of BH4^13–22^ in patients with PKU. Phe levels were reduced by at least 30 percent (the level used in studies submitted to the FDA to assess responsiveness) in up to half of treated participants (32 to 50 percent) at dosages of 5 to 20 mg/kg/day and for up to 22 weeks of observation in comparative studies. In the one RCT that comparing the effect of placebo on likelihood of a 30 percent reduction in Phe, only 9 percent of those on placebo achieved this effect, compared with 44 percent of the treated group after 6 weeks.14 Data from the uncontrolled open label trial following 13 this RCT14 suggested a sustained response for up to 22 weeks duration, with a 46 percent achieving a 30 percent reduction in Phe levels. Two trials15,18 also examined the effect of BH4 use on Phe tolerance in individuals responsive to BH4, as did three case series.17,19,21 In all five studies, Phe tolerance improved over time. One small case series reported on IQ and nutritional outcomes for up to 1 year on 5 mg/kg/day BH4 treatment.19 After 1 year of treatment, the 11 participants discontinued use of a medical food and normalized their diet. IQ scores after 12 months on BH4 were similar to scores before treatment and development quotients were within normal limits.

Of the 10 studies examining the effectiveness of BH4 in participants with PKU, 4 studies13–15,20 reported any type of harm related to the intervention drug. The most common side effects reported during BH4 trials were headache, throat pain, upper respiratory infection, diarrhea, abdominal pain, and nausea and vomiting, but harms were not significantly more common in the treatment arm than in the placebo.

#### LNAAs

Three studies addressed the effects of LNAAs.2,23,24 The studies included a total of 47 participants. The trials were short, with treatment between 1 and 8 weeks, and dosages ranged from 250 mg/kg/day to 1g/kg/day. Two of the three studies measured reductions in Phe levels,2,24 and one assessed cognitive outcomes.23 This fair quality study23 reported a positive effect on executive functioning, specifically verbal generativity, cognitive flexibility, and self-monitoring. Overall, participants who were using a Phe-free medical food to their nutritional needs did not experience a decrease in Phe, although those not adhering to diet or not using their formula did. In all three studies, blood Phe decreased after one week of treatment but remained above clinically acceptable levels. One trial of LNAAs23 assessed neuropsychological outcomes and reported higher rates of anxiety associated with LNAA use.

#### Subgroups of Individuals With PKU

We did not identify any studies meeting our criteria and addressing adjuvant therapies in pregnant women with PKU of the effectiveness of adjuvant therapies for subgroups of individuals with PKU.

#### Strength of Evidence

Table 1 outlines the strength of the evidence (confidence that the current effect estimate will not change with future research) for the effects of BH4 and LNAAs as determined in the review.

Table 1 Intervention, strength of evidence domains, and strength of evidence for key outcomes

Outcome | Intervention | Study Type (N studies of type reporting outcome) | Risk of Bias | Consistency | Directness | Precision | SOE
Reduction in Phe levels over the short term (≤12 weeks) in responders | BH4 | RCT (2)14,15 Uncontrolled open label (3)13,18,20 Case series (3)16,19,21 | Medium | Consistent | Direct | Precise | Moderate
Reduction in Phe levels over the short term (≤12 weeks) in responders | LNAAs | RCT (2)23,24 Uncontrolled open label (1)2 | High | Inconsistent | Direct | Imprecise | Insufficient
Reduction in Phe levels over the long term (>12 weeks) in responders | BH4 | Case series (4)16,17,19,21 | High | Consistent | Direct | Imprecise | Insufficient data to calculate an effect
Phe tolerance | BH4 | RCT (1)15 Uncontrolled open label (1)18 Case series (3)17,19,21 | High | Consistent | Direct | Imprecise | Insufficient
Phe tolerance | LNAAs | NR | NR | NR | NR | NR | Insufficient
Phe variability | BH4 | Case series (1)16 Cohort study (1)22 | High | Unknown | Direct | Imprecise | Insufficient
Phe variability | LNAAs | NR | NR | NR | NR | NR | Insufficient
Cognitive outcomes | BH4 | Case series (1)19 plus indirect evidence from RCTs plus meta-analysis | High | Unknown | Direct | Imprecise | Low
Cognitive outcomes | LNAAs | RCT (1)23 | High | Unknown | Direct | Imprecise | Insufficient
Nutritional status | BH4 | Case series (1)19 | High | Unknown | Direct | Imprecise | Insufficient
Nutritional status | LNAAs | NR | NR | NR | NR | NR | Insufficient
Lack of significant harms | BH4 | RCT (2)14,15 Uncontrolled open label (2)13,20 Cohort study (1)22 | High | Consistent | Direct | Precise | Moderate
Lack of significant harms | LNAAs | RCT (1)23 | High | Unknown | Direct | Imprecise | Insufficient
Quality of life | BH4 | NR | NR | NR | NA | NR | Insufficient
Quality of life | LNAAs | NR | NR | NR | NA | NR | Insufficient

Abbreviations: LNAAs=large neutral amino acids; NA=not applicable; NR=not reported; RCT=randomized controlled trial; SOE=strength of the evidence

## Evidence Gaps

The existing research gaps related to the use of adjuvant pharmacologic therapy in PKU are both substantive and methodologic. Research is fundamentally challenging because the disease is so rare, making accrual of adequate numbers of participants difficult, if not impossible, for some studies. Furthermore, in part because it affects so few people, funding for PKU research is limited, and to date, treatment research is almost exclusively supported by the pharmaceutical industry.

### Phe Level and Cognitive Outcomes

A significant limitation in the current body of research on the relationship between blood Phe level and cognitive outcomes is the lack of consistent methodologies using standardized tools and measures and consistent data collection across centers. The result is that many studies provide incomplete data that cannot be used in meta-analyses, despite a clear need for research to occur across sites in order to accrue adequate numbers for analysis. Complete reporting of data and results in future studies would ensure that future research can be considered in more robust meta-analyses and can contribute to an improved understanding of the relationship between Phe and IQ.

In addition, some studies that did provide appropriate data for inclusion did not provide information on potentially confounding or modifying factors in the relationship between Phe and IQ. In future research, details about familial IQ, socioeconomic status, maternal education, age at initial treatment and concurrent medications should be fully described so they might be used in a more extensive meta-analysis of Phe-IQ associations. One basic need is to better understand the degree to which the perceived association changes by age, with the practical implication of understanding the degree of dietary control necessary across age groups. Certainly if patients are able to adhere to diet, then tight control is the standard of care, but understanding of the specific implications of looser control, especially in older adults, is lacking and could inform clinical practice. Because tight control is important, an understanding is needed of the supports that might be helpful as individuals age over the lifespan. Related to this is the need for additional measures to assess adequate control beyond blood Phe. This requires an understanding of what outcomes are clinically important, and their relative value to patients and their families. For this to be possible, complete and accurate measure of Phe and cognition over fairly long periods of time is necessary, perhaps through a long-term follow up study or through the multisite collaboration suggested above. Finally, the effects of mild hyperphenylalaninemia as opposed to classic, mild and moderate PKU, should also be clarified, including the impact on cognition, executive functioning, attention, behavioral problems, and other psychological issues.

Ideally, future studies or a complete registry could provide repeated measures (e.g., index of dietary control) of blood Phe that can more precisely characterize an individual’s Phe level over relevant time intervals, and standard deviations around those measures so that we can determine the effect of variation in Phe on IQ. Also, rather than relying solely on IQ, alternative outcomes could allow for modeling the degree to which increased Phe is associated with differences between an individual’s realized and expected outcomes.

Although research is being conducted on executive function outcomes for individuals with PKU, there is no consensus on which measures of executive function are most appropriate. This highlights the need for fundamental research, because measures of executive function tend to be better reflections of success with day-to-day activities than targeted measures such as IQ. It is plausible that some measures of executive function may be more sensitive to changes in Phe than IQ, and therefore better at identifying impairment. By the same token, establishing the degree to which measures of executive function can and should be combined in analyses would be helpful for synthesizing the currently disparate body of literature. Nonetheless, the sensitivity, validity and acceptability of individual executive function measures in PKU has yet to be established or agreed upon, and current research reflects a reliance on a wide range of outcomes, making synthesis of relationships and pooling of results difficult.

Given the reported association between PKU and an increased incidence of inattention, anxiety and depressive symptoms, additional studies on these and other psychological issues in PKU are also warranted. Some of this work is ongoing, and we encourage more work examining the full range of outcomes associated with PKU.

### BH4

Research on the use of BH4 as an adjuvant therapy in PKU management consists of small, tightly controlled multisite efficacy studies, two of which are RCTs. The greatest research need in this area is thus for larger studies. Given the known difficulty of accruing large numbers of participants, however, researchers should also use existing data sets, and, as recommended, use a consortium and multisite approach to gathering data. Ideally, studies will be conducted in both tightly controlled and nonadherent populations, and among different age groups, with appropriate design and power for subgroup analyses. Research should continue to include RCTs, but prospective cohort studies that may have the potential to provide additional effectiveness data—including outside of a controlled clinical setting—adherence and longer term evidence would also be helpful to support understanding of the role of BH4 in clinical care. These studies should provide substantially more detail on the range of benefits and harms associated with treatment. For example, a better understanding is needed of the effects of BH4 in children less than 4 years of age and pregnant women, and while it may be challenging or inappropriate to conduct RCTs in these populations, observational cohorts or registry data are essential.

Data are not currently available to understand potential modifiers of treatment effectiveness in order to select the best populations for targeting further research and treatment. Moreover, the variability in responsiveness to BH4 is unexplained, and subpopulations that have a unique response to this medication have not been well characterized. Causes of variability may be multifactorial and likely include individual patient and genotype differences, drug dose, and individual patient behavior such as dietary adherence. It is unclear, in particular, why a high proportion of individuals who have an initial response in loading studies at screening do not have a durable response in efficacy trials, even while those who do have a response demonstrate a significant effect. The degree to which this observed variation may be associated with suboptimal adherence should be assessed.

Another area of potential research is the use of adherence supports for both drug and diet to optimize potentially positive outcomes. It is assumed that support at familial, social and system levels may be helpful and this idea should be empirically addressed.

Long-term efficacy outcomes beyond 22 weeks and safety outcomes beyond 3 years are currently unavailable, as are measures of behavioral change and cognition and patient-reported outcomes including quality of life. The degree to which reductions in blood Phe are associated with measurable cognitive outcomes or even patient perception of increased mental clarity is unknown. Furthermore, explicit assessment of the potential for liberalization of the diet, and the subsequent nutritional effects has yet to be conducted.

Future research should comprise larger studies designed to allow subgroup analysis of the effectiveness of adjuvant pharmacologic therapy for PKU. Although the current literature does not provide evidence for effectiveness in all target patients, some benefit is seen in some patients. Whether these patients differ from the overall population in terms of genotype is an area of current research focus that has the potential to allow targeting of treatment.

A number of studies are reportedly underway to address gaps in the current literature. These include a long-term study of the effect of BH4 on neurocognitive function in young children, a study of the effect in adolescent patients with attention deficit hyperactivity disorder, and a registry that includes pregnant women. However, we stress the importance of making data available and note that several commitment studies have been listed as completed, but have yet to make findings available. These include the studies on cardiac effects of BH4. Another commitment study that is reported as fulfilled is an open label study to study the safety and efficacy of BH4 for treating patients with hyperphenylalaninemia, yet no results have been made available. Finally, publicly funded studies to confirm and expand on reported efficacy and effectiveness data are needed.

### LNAAs

The three very small studies of LNAAs cannot be considered as more than proof of concept at this time, and if further work is to occur in this area, it should be done in well-conducted RCTs of adequate size. The mechanism by which LNAAs may work should be clarified, as should the optimal target population and specific treatment goals. The current formulations that have been tested require taking many pills per day and so the formulations should be made more palatable.

Figure 1 illustrates these treatment-related evidence gaps within the analytic framework of the evidence report.

Figure 1 Analytic framework illustrating intervention-related evidence gaps

The analytic framework illustrates the relationship between infants, children, adolescents, and adults with PKU and females with PKU who become pregnant, treatment choices for PKU, monitoring, outcomes, and harms. Patients may choose a Phe-restricted diet alone or a Phe-restricted diet in conjunction with treatment with sapropterin dihydrochloride or large neutral amino acids, followed by monitoring of Phe levels. Depending upon the Phe level the treatment may be altered. Therapies may lead to intermediate and long-term outcomes and harms. Intermediate treatment outcomes include decreased Phe levels in the blood and improved Phe tolerance. Therapies may also lead to long term outcomes, including changes in quality of life, normal growth, nutritional outcomes, and cognitive development. Outcomes in infants of mothers with PKU include the prevention of neurologic impairment and cardiac defects and normal growth. Research gaps occur at multiple points in the process and include a lack of: • Understanding of effects of BH4 in subpopulations including young children and pregnant women with PKU • Understanding of modifiers of treatment effects • Larger, long-term studies of adjuvant therapies • Understanding of treatment goals and optimal target population • Understanding of cognitive and behavioral effects and appropriate measures • Understanding of responsiveness to BH4 • Understanding of outcomes of importance to patients • Understanding of factors affecting adherence • Understanding of harms over the long term.