# Summary of Stakeholder Calls

Future Research Needs—Adjuvant Therapies for Phenylketonuria

May 15 and 16, 2012 Stakeholder Call Summary

## Objective

To review and expand on research gaps and potential research questions outlined in the Adjuvant Therapies for PKU comparative effectiveness review in preparation for prioritizing research needs identified.

The team and stakeholders reviewed the preliminary list of gaps identified by key question. Stakeholders offered suggestions for additional questions, refinements to questions, and additional points to consider. We summarize stakeholder discussion by Key Question below. Tables following the summary reflect additional questions/points suggested by stakeholders.

### Key Question 1 (Evidence for specific Phe levels in minimizing cognitive impairment)

- Stakeholders suggested referencing the grid developed during NIH PKU state of the science meeting and outlining cognitive screening tools and screenings by age.
- Stakeholders agreed that establishing the validity of measures of cognition and executive function is a critical issue.
- Stakeholders noted difficulty in understanding issues related to attention--is the incidence of ADHD increased in the PKU population versus the general population or are attention-related symptoms in PKU due to effects of Phe levels? To what extent is ADHD a comorbidity of PKU or a feature of the PKU phenotype?
- Stakeholders also noted a lack of understanding of the effectiveness of ADHD medications in individuals with PKU.
- Stakeholders recommended specific questions dealing with the validity and sensitivity of measures to assess ADHD in PKU.
- Stakeholders noted that measures of executive function may not assess real world functioning; questions should clearly note that a clinical measure and assessment of real world/adaptive functioning are important. A grid developed by the PKU NIH conference long-term functioning workgroup may be useful as background material. Suggested research issues include: to what degree does Phe level affect domains of social and emotional functioning? What is the relationship between clinical measures of executive function and real world functioning?
- Stakeholders also noted the importance of understanding the relationships among executive function deficits, other cognitive deficits, and educational functioning in PKU.
- Stakeholders suggested that questions about the validity of measurements also address a tool’s responsiveness to change.
- Stakeholders noted that nutritional status can affect cognitive function. Research is needed to address biomarkers and techniques to measure nutritional status, the impact of nutritional status on health and thus on cognition and measure of emotion or conditions such as anxiety.
- Understanding the role of neuroimaging in PKU is an additional area to consider.
- An important question that remains unanswered is what is the mechanism by which elevated Phe (or its metabolites) is toxic to the brain and affects cognition?

### Key Question 2 (Effects of BH4 on Phe, cognition, QoL, and nutritional status)

- Stakeholders and team noted that research on BH4 related to effects in young children and longer-term outcomes is in process. Stakeholders noted that while currently ongoing research will provide valuable insight, it will not be able to answer questions related to long-term outcomes.
- Stakeholders recommended revising the wording of some questions to clarify that diet is the standard of care, despite variation in adherence to diet.
- Stakeholders noted that while answering comparative effectiveness questions is critical, the final report should acknowledge that answers to questions/the research base are not sufficient for informing policy decisions. Such decisions must weigh effects on outcomes including family functioning, quality of life, nutritional status, and cognition.
  Comparative effectiveness research (CER) should acknowledge the gap between the CER process and the reality of implementing policy and care. CER can improve efforts to incorporate contextual information in order to increase utility.
- Stakeholders noted that a high percentage of adults with PKU are currently not under clinical care. New treatments may serve to draw people back to the clinic and potentially to diet/adjuvant treatment.
- Stakeholders noted that a potential research area is exploring the effects of adjuvant therapy (BH4 or LNAAs) in promoting a return to care and in modifying the process of care. Research should address how to identify patients not under care and the best ways to reach this population as well as how adjuvant therapy may affect the transition to care as an adult.
- Another area of research recommended by stakeholders relates to defining responsiveness to BH4 treatment and whether responsiveness as defined by Phe levels or tolerance differs from responsiveness as defined by changes in cognition or other long-term outcomes.
- Stakeholders also recommended that research address the optimal study duration for assessing cognitive or other effects.
- Family functioning was recommended by stakeholders as both an outcome of interest and potential modifier of treatment effectiveness; stakeholders noted that defining/developing a valid measure of family functioning will be necessary.

### Key Question 3 (Effects of BH4 in pregnant women with PKU)

- Stakeholders strongly supported the use of registry data and data that is available to address questions in pregnant women and noted a need to ensure that registry data collection is modified to collect efficacy data appropriately. The team discussed the drawbacks of a lack of comparative data (women not treated with BH4) in registries but noted the potential to use historical data.
- Stakeholders noted that, despite the fact that little is known about safety of BH4 in pregnant women, a lack of dietary restriction will lead to poor outcomes.

### Key Question 4 (Effects of LNAAs on cognition, QoL, and nutritional status)

- Despite the lack of existing high quality research suggesting benefit for LNAAs, stakeholders agreed that further research on LNAAs is critical.
- Stakeholders noted that critical areas for research are finding CNS markers for changes in neurotransmitters, understanding if amino acid/precursor production leads to neurotransmitter production, understanding how to measure brain amino acid absorption, and understanding the role and potential of spectroscopy to assess amino acid changes. Significant work needs to be done to understand technologies for measuring brain effects. Stakeholders noted that animal models for understanding protein synthesis and blood-brain Phe transport would be useful and that some for PKU in general do exist.
- Stakeholders agreed that monitoring Phe levels in the brain would be useful in PKU in general; validating biomarkers that would demonstrate either response to treatment or therapeutic efficacy across the board is important.
- Stakeholders felt that outcomes of interest for questions related to the effectiveness of LNAAs should emphasize cognition and executive function (vs. effects on Phe). It is also important to understand how and how often to measure effects on outcomes of LNAA use.
- Stakeholders brought up the need to understand combination therapies and noted that the use of combination therapies will outstrip the research, thus understanding safety and efficacy is critical. Questions include the role of combination therapy in PKU and how to measure effectiveness.

### Key Question 7 (Evidence of treatment effectiveness for subgroups of individuals with PKU) and overarching issues

- Team noted that understanding adherence in subgroups is an area for research: What are the particular drivers of adherence both to diet and drug in this population? What motivates adherence, at what age groups? Stakeholders noted that there may be critical developmental periods for promoting adherence to promote lifelong care.
- Stakeholders noted a need to understand markers of treatment effectiveness better. Blood Phe is not the ideal ultimate outcome, but understanding of the sensitivity of other measures is lacking. The Phe-Tyrosine ratio may be a good candidate for further study.
- Stakeholders noted a need to understand the overlap of cognitive effects due to vitamin and mineral deficiencies and cognitive and neuro-cognitive outcomes related to PKU itself. A pressing research question is how to differentiate between outcomes as a result of the disease versus those as a result of a dietary deficiency. In patients who consume adequate amounts of medical foods, it is not known whether those adequately meet nutritional needs across life stages.
- Stakeholders agreed that an understanding of the natural history of PKU is lacking as is an understanding of outcomes at older ages.
- Stakeholders indicated a need for standardized data collection tools for dietary analysis.
- Stakeholders also discussed the implications of spotty insurance coverage of medical foods after age 18 and implications both for the individual and for research if a significant number of individuals cannot maintain the standard of care.
- Stakeholders and the team discussed the need to explore alternate means of data collection as trial accrual in rare diseases is slow and there is a need to study outcomes in pregnant women while maximizing safety. Registries and observational studies can provide useful data but research should explore ways to modify registry data collection so that efficacy data is collected appropriately. The final report should include a summary of novel study designs and considerations for each.
- Stakeholders noted that the report should also acknowledge new therapies beginning to be studies including newer formulations of LNAAs, PegPAL, and glycomacropeptide (GMP) protein formulas. Additionally, stakeholders noted that the goal of therapy is to maximize outcomes for the patient, so clinicians may prescribe medications such as anxiolytics. Research should begin to study the effects of additional treatments in individuals with PKU and to understand the real world effects of combination therapies.
- Stakeholders advocated research exploring means to monitor Phe levels more easily.
- Stakeholders noted that an understanding of how to incorporate the patient perspective in determining relevant study end points is important as is incorporating measures of quality of care as outcomes of research.
- Stakeholders commented that ensuring a skilled workforce is increasingly critical as individuals with PKU age. Clinicians and nutritionists need training appropriate for understanding unique needs in metabolic disease.

## Research Questions Derived from Gaps Noted in Report and Stakeholder Additions by Key Question

### Key Question 1a. What is the evidence that any specific Phe levels are optimal for minimizing or avoiding cognitive impairment in individuals with PKU? Key Question 1b. What is the evidence that different target Phe levels are appropriate for minimizing or avoiding cognitive impairment for different age groups?

# | Research Questions Derived from Report | Potentially Relevant Ongoing Research
1 | Which domains of executive function (e.g., planning, inhibitory control) are most sensitive to changes in Phe in individuals with PKU? | --
2 | Which measures, including executive function and affective disorder screens, are shown to be associated with to changes in cognitive outcomes related to Phe level in individuals with PKU? | --
3 | To what degree do measures of executive function vary with cognition, in the context of varying levels of Phe? | --
4 | What is the validity, reliability, and responsiveness to change of existing tools for measuring executive function in individuals with PKU? | --
5 | When measuring executive function in individuals with PKU, when and how frequently should these measures be assessed? | --
Additional Questions from Stakeholder Calls
1 | Which measures of ADHD are valid, sensitive, and reliable for use in individuals with PKU?
2 | What are the clinical benefits and limitations of distinguishing attention-related symptoms due to elevated Phe levels vs. from non-PKU-related factors such as individual behavior?
3 | To what degree does Phe level affect domains of social and emotional functioning in PKU?
4 | What is the relationship between clinical measures of executive function and “real world”/adaptive functioning?
5 | Which measures, including executive function and affective disorder screens, are shown to be associated with to changes in “real world”/adaptive functioning related to Phe level in individuals with PKU?
6 | What are the effects of nutritional status on measures of executive function or emotion?
7 | To what extent are poor cognitive outcomes related to dietary deficiencies compared with Phe levels?

### Key Question 2 What is the comparative effectiveness of BH4 with dietary intervention versus dietary intervention alone for affecting outcomes including measures of cognition (including executive function), quality of life, and nutritional status?

# | Research Questions Derived from Report | Potentially Relevant Ongoing Research
1 | In children ≤4 years old with PKU, what is the effect of BH4 plus diet compared with placebo plus diet or standard care on Phe control, cognitive outcomes (IQ and measures of executive function), QOL, liberalization of diet, and growth and development? | - PKUDOS: Phenylketonuria (PKU) Demographic, Outcomes, and Safety Registry (NCT00778206); - Kuvan® Adult Maternal Pediatric European Registry (KAMPER): Observational Study on the Long Term Safety of Kuvan® Treatment in Patients With Hyperphenylalaninemia (HPA) Due to Phenylketonuria (PKU) or BH4 Deficiency (NCT01016392); - Safety, and Population Pharmacokinetics of Sapropterin Dihydrochloride (Kuvan®) in Phenylketonuria (PKU) Patients <4 Years Old. (SPARK) (NCT01376908); - A Phase 3b Open-Label Study to Evaluate the Effect of Kuvan® on Neurocognitive Function, Maintenance of Blood Phenylalanine Concentrations, Safety, and Population Pharmacokinetics in Young Children With Phenylketonuria (NCT00838435)
2 | In individuals with PKU responsive to BH4, what is the effect of BH4 plus diet compared with diet/standard care on outcomes including Phe control, Phe tolerance, cognitive outcomes (IQ and executive function), quality of life, liberalization of diet, family functioning, and harms of treatment over the long term (>2 years)? | - PKUDOS: Phenylketonuria (PKU) Demographic, Outcomes, and Safety Registry (NCT00778206); - Kuvan® Adult Maternal Pediatric European Registry (KAMPER): Observational Study on the Long Term Safety of Kuvan® Treatment in Patients With Hyperphenylalaninemia (HPA) Due to Phenylketonuria (PKU) or BH4 Deficiency (NCT01016392)
3 | What characteristics of the individual or family moderate responsiveness to BH4 in individuals with PKU? | - PKUDOS: Phenylketonuria (PKU) Demographic, Outcomes, and Safety Registry (NCT00778206); - Kuvan® Adult Maternal Pediatric European Registry (KAMPER): Observational Study on the Long Term Safety of Kuvan® Treatment in Patients With Hyperphenylalaninemia (HPA) Due to Phenylketonuria (PKU) or BH4 Deficiency (NCT01016392)
4 | What is the comparative effectiveness of BH4 in addition to diet, relative to diet alone, to reduce behavioral and psychological comorbidities in individuals with PKU? | - PKUDOS: Phenylketonuria (PKU) Demographic, Outcomes, and Safety Registry (NCT00778206); - Kuvan® Adult Maternal Pediatric European Registry (KAMPER): Observational Study on the Long Term Safety of Kuvan® Treatment in Patients With Hyperphenylalaninemia (HPA) Due to Phenylketonuria (PKU) or BH4 Deficiency (NCT01016392); - A Double-blind, Placebo-controlled, Randomized Study to Evaluate the Safety and Therapeutic Effects of Sapropterin Dihydrochloride on Neuropsychiatric Symptoms in Subjects With Phenylketonuria(NCT01114737)
5 | What characteristics of the individual, including disease severity, or characteristics of the family are associated with early vs. late initial response to BH4? | --
Additional Questions from Stakeholder Calls
1 | In individuals with PKU not currently adherent to diet or receiving treatment for PKU, what are the effects of BH4 in promoting return to care?
2 | How does treatment with BH4 modify other care processes, including the transition to care as an adult?

### Key Question 3 What is the comparative effectiveness of BH4 with dietary intervention versus dietary intervention alone in pregnant women with PKU for affecting outcomes in their infants, including prevention of neurological impairment, microcephaly, and cardiac defects?

# | Research Questions Derived from Report | Potentially Relevant Ongoing Research
1 | In pregnant women with PKU, what is the effect of BH4 plus diet compared with placebo plus diet or standard care on Phe control, cognitive outcomes (IQ and measures of executive funtion), QOL, liberalization of diet, and pregnancy outcomes? | - PKUDOS: Phenylketonuria (PKU) Demographic, Outcomes, and Safety Registry (NCT00778206); - Kuvan® Adult Maternal Pediatric European Registry (KAMPER): Observational Study on the Long Term Safety of Kuvan® Treatment in Patients With Hyperphenylalaninemia (HPA) Due to Phenylketonuria (PKU) or BH4 Deficiency (NCT01016392)
2 | What harms to the mother and offspring are associated with BH4 use in pregnant women with PKU? | - PKUDOS: Phenylketonuria (PKU) Demographic, Outcomes, and Safety Registry (NCT00778206); - Kuvan® Adult Maternal Pediatric European Registry (KAMPER): Observational Study on the Long Term Safety of Kuvan® Treatment in Patients With Hyperphenylalaninemia (HPA) Due to Phenylketonuria (PKU) or BH4 Deficiency (NCT01016392)

### Key Question 4 What is the comparative effectiveness of LNAAs with dietary intervention versus dietary intervention alone for affecting outcomes including measures of cognition (including executive function), quality of life, and nutritional status?

# | Research Questions Derived from Report | Potentially Relevant Ongoing Research
1 | In individuals with PKU, what are the long-term effects (>6 months) of LNAAs on cognitive outcomes (IQ and executive function), quality of life, and liberalization of diet and harms of LNAAs? | - Effects of short term increase of phenylalanine levels on neuropsychological functions and well-being in adults with phenylketonuria: the “diet for life” study- supplement of amino acids (NTR1056)
2 | What harms are associated with LNAA use in individuals with PKU? | - Effects of short term increase of phenylalanine levels on neuropsychological functions and well-being in adults with phenylketonuria: the “diet for life” study- supplement of amino acids (NTR1056)
Additional Questions from Stakeholder Calls
1 | What is the effectiveness of spectroscopy or other imaging techniques in assessing the effects of LNAAs on neurotransmission of Phe?
2 | What CNS biomarkers are effective for assessing the effects of LNAAs on the brain in individuals with PKU?
3 | In individuals with PKU not currently adherent to diet or receiving treatment for PKU, what are the effects of LNAA in promoting return to care?
4 | How does treatment with LNAAs modify other care processes?
5 | How can the effects of LNAAs be measured and when should measurement occur?
6 | What methods are affective for measuring brain amino acid absorption?

### Key Question 7 What is the evidence for the effectiveness of the addition of BH4 or LNAAs to dietary intervention for affecting outcomes in subgroups of patients?

# | Research Questions Derived from Report | Potentially Relevant Ongoing Research
1 | What are short-term effects of BH4 on outcomes including Phe control, Phe tolerance, cognitive outcomes (IQ and executive function), quality of life, and liberalization of diet, and harms of BH4 in specific subgroups (defined by age, dietary control, disease type)? | - PKUDOS: Phenylketonuria (PKU) Demographic, Outcomes, and Safety Registry (NCT00778206); - Kuvan® Adult Maternal Pediatric European Registry (KAMPER): Observational Study on the Long Term Safety of Kuvan® Treatment in Patients With Hyperphenylalaninemia (HPA) Due to Phenylketonuria (PKU) or BH4 Deficiency (NCT01016392); - Effects of Sapropterin on Brain and Cognition in Individuals With Phenylketonuria (NCT00730080); - Evaluation of Behavior, Executive Function, Neurotransmitter Function and Genomic Expression in PKU “Nonresponders” to Kuvan(NCT01274026); - Treatment of hyperphenylalaninemia with Sapropterin dihydrochloride (tetrahydrobiopterin, 6R-BH4) and its influence on the amino acids and fatty acids patterns from childhood to adulthood, a Phase IV, longitudinal, unblinded, controlled, single-centre, retrospective and prospective clinical study(ISRCTN77098312)

## Overall/Foundational Questions Derived from Report

# | Research Question | Potentially Relevant ongoing Studies
1 | Among individuals with PKU using pharmacologic therapy, are supportive adherence models effective in increasing adherence? | --
2 | Are supportive adherence models (diet and/or drug) effective at improving long-term cognitive outcomes? | --
3 | Among effective adherence support systems, have individual components been shown to drive effectiveness? | --
4 | Is the effectiveness of adherence models moderated by characteristics of the individual, including age, gender, family structure and severity of disease? | --
5 | What are the pharmacokinetic, pharmacodynamic, and pharmacogenomic factors associated with treatment response in individuals with PKU? | --
6 | Are passive registries as effective as ongoing cohort studies for collecting adequate data to assess long-term effectiveness of adjuvant therapies? | - PKUDOS: Phenylketonuria (PKU) Demographic, Outcomes, and Safety Registry (NCT00778206); - Kuvan® Adult Maternal Pediatric European Registry (KAMPER): Observational Study on the Long Term Safety of Kuvan® Treatment in Patients With Hyperphenylalaninemia (HPA) Due to Phenylketonuria (PKU) or BH4 Deficiency (NCT01016392)
7 | In addition to blood Phe, what measures provide valid assessments of dietary control in individuals with PKU? | - PKUDOS: Phenylketonuria (PKU) Demographic, Outcomes, and Safety Registry (NCT00778206); - Kuvan® Adult Maternal Pediatric European Registry (KAMPER): Observational Study on the Long Term Safety of Kuvan® Treatment in Patients With Hyperphenylalaninemia (HPA) Due to Phenylketonuria (PKU) or BH4 Deficiency (NCT01016392)
8 | What are the components of an effective system of care for individuals with PKU? | --
9 | What treatment-related factors at different ages are the greatest source of concern to families/caregivers? | - 5-year Follow-up of the Comparison of Life and Physical Health in Adult Patients With PKU and Healthy Age Matched Controls (NCT01096758)
10 | In individuals with PKU, what timing of Phe monitoring is optimal for fine tuning diet and treatment? | - The effects of online availability of individual phenylalanine levels to patients with phenylketonuria (NTR1171)
Additional Questions from Stakeholder Calls
1 | What medical supports can bring individuals with PKU back to treatment and/or dietary adherence?
2 | Which biomarkers are effective for demonstrating response to treatment or therapeutic efficacy in PKU?
3 | What is the utility of the plasma Phe/Tyrosine ratio compared with plasma Phe level as a measure of Phe control in PKU?
4 | Are medical foods adequate to overcome vitamin and mineral deficiencies over the lifetime in individuals with PKU?
5 | What biomarkers are valid for understanding the effects of vitamin and mineral deficiencies in PKU?
6 | What is an appropriate study duration for understanding cognitive and other effects in individuals with PKU?
7 | How can nutritional status be effectively measured in PKU?
8 | What is the role of functional neuroimaging in PKU?
9 | What is the role of combination therapy in PKU?
10 | How can the effectiveness of combination therapies be measured?
11 | How should registry data collection be modified to allow for collection of efficacy data?
12 | Are there critical periods of development during which promotion of adherence would facilitate long-term adherence to care?

### Additional (non-research) recommendations/needs

- Increased understanding of long-term implications of intermediate outcomes
- Multi-collaborator consortium that includes a public-private partners to outline research agenda; evaluate needs for comprehensive system of care; develop/expand prospective registries to include collection of outcome data including measures of executive function, nutritional status, growth, and quality of life; and biorepository
- Understanding of the role of international collaboration and differences in diet, culture, genotype/phenotype, etc. in planning for multicenter consortia
- Standardized data collection tools, especially for cognitive outcomes
- Standards/guidelines for data sharing and comprehensive reporting (including reporting of measures of variance, potential confounding and modifying factors, etc.)
- Standardized collection and reporting of potential confounders and modifiers (e.g., familial IQ, SES, maternal education, concurrent medications, age at initial treatment, level of dietary control)
- Increased understanding of outcomes of importance to patients and families
- Understanding of quality of life for patients and families and factors that affect quality of life
- Understanding approaches to studying adjuvant therapies in pregnant women with PKU (e.g., registry, cohort study)
- Understanding of study designs that can provide high-quality data while taking into account difficulties in accrual in rare
- Studies appropriately designed and powered to allow subgroup analyses
- Understanding of the potential role of observational studies in providing effectiveness data
- Publicly funded studies
- Understanding of potentially useful research models from other rare diseases

### Additional points from stakeholder calls

- Need for standardized dietary data collection tools
- Need to understand how well medical foods meet nutritional needs across the lifespan
- Understanding of the effects of lack of insurance coverage of medical foods and treatment needs after age 18/26 for many individuals with PKU and individual and research implications for maintaining the standard of care
- Exploration of techniques to monitor Phe levels more easily, including home monitoring
- Understanding of methods for incorporating the patient perspective in determining relevant study end points
- Animal studies to increase understanding of protein synthesis and blood-brain transport and mechanisms of toxicity of Phe and/or its metabolites in the brain
- Appropriate training to ensure knowledgeable workforce as case identification increases with newborn screening
- Appropriate training for non-metabolic nutritionists in understanding exigencies of PKU
- Appropriate training for psychiatrists and psychologists in understanding PKU
- Understanding of how to incorporate quality of care as an outcome

### Additional Questions from Stakeholder Calls—Out of Scope of Adjuvant Therapies (will be noted in final report but not prioritized by stakeholders)

- What is the effectiveness of medications to treat ADHD, anxiety, depression, and other mental health comorbidities in individuals with PKU?
- What methods are effective for identifying and reaching individuals with PKU not currently under care?
- What is the natural history of PKU?
- How does defining responsiveness in terms of Phe level or Phe tolerance or in terms of cognition or other long-term outcomes affect care for individuals with PKU?

### Next Steps

We will send stakeholders the link to a Web-based survey to prioritize the expanded list of research needs. Prioritization will occur in two rounds: In the first round stakeholders will allot a number of points to each question to indicate the top tier/highest priority questions. We will compile “votes” across stakeholders and cull the expanded list to the highest priority research needs. In the second round, stakeholders will prioritize the top tier list of needs using criteria including the potential for significant health impact, potential for risk from inaction, and potential for significant economic impact.