# Highest Ranking Questions by Prioritization Criteria

We present the highest ranking (top 5) research needs/questions for each prioritization criterion organized by broad area of focus (treatment- or methods-related). Questions appear in alphabetical order under each criterion. Prioritization criteria were as follows:

- Potential for significant health impact
- Potential to reduce variation in clinical practices
- Potential for significant economic impact
- Potential risk from inaction.
- Potential to address inequities
- Potential to allow assessment of ethical, legal, social issues pertaining to the condition
- Potential for new knowledge.

## Treatment Questions

Table D-1 Highest ranking treatment-related questions by prioritization criterion

Potential for significant health impact
Do interventions intended to increase adherence to diet or drug treatment in individuals with PKU lead to improved short-term and long-term cognitive outcomes? Are promotion of adherence and related positive outcomes that occur over the long term modified by important factors that include developmental stage of the individual, age, family factors, Phe level, historical adherence, and type of PKU?
In children ≤4 years old with PKU, what is the effect of BH4 plus diet compared with placebo plus diet / standard care on Phe control, cognitive outcomes (IQ and measures of executive function), QOL, liberalization of diet, and growth and development?
In individuals with PKU responsive to BH4 plus diet compared with diet/standard care on outcomes including Phe control, Phe tolerance, cognitive outcomes (IQ and executive function), quality of life, liberalization of diet, family functioning, and harms of treatment over the long term (>2years)?
In pregnant women with PKU, what is the effect of BH4 plus diet compared with placebo plus diet / standard care on Phe control, cognitive outcomes (IQ and measures of executive function), QOL, liberalization of diet, and pregnancy outcomes?
What is the comparative effectiveness of BH4 in addition to diet, relative to diet alone, to reduce behavioral and psychological co-morbidities in individuals with PKU?
Potential to reduce variation in clinical practices
Do interventions intended to increase adherence to diet or drug treatment in individuals with PKU lead to improved short-term and long-term cognitive outcomes? Are promotion of adherence and related positive outcomes that occur over the long term modified by important factors that include developmental stage of the individual, age, family factors, Phe level, historical adherence, and type of PKU?
In individuals with PKU not currently adherent to diet or receiving treatment for PKU, what are the effects of BH4 in promoting return to care?
In pregnant women with PKU, what is the effect of BH4 plus diet compared with placebo plus diet / standard care on Phe control, cognitive outcomes (IQ and measures of executive function), QOL, liberalization of diet, and pregnancy outcomes?
What are the components of an effective system of care for individuals with PKU?
What is the comparative effectiveness of BH4 in addition to diet, relative to diet alone, to reduce behavioral and psychological co-morbidities in individuals with PKU?
Potential for significant economic impact^*^
Do interventions intended to increase adherence to diet or drug treatment in individuals with PKU lead to improved short-term and long-term cognitive outcomes? Are promotion of adherence and related positive outcomes that occur over the long term modified by important factors that include developmental stage of the individual, age, family factors, Phe level, historical adherence, and type of PKU?
In individuals with PKU responsive to BH4 plus diet compared with diet/standard care on outcomes including Phe control, Phe tolerance, cognitive outcomes (IQ and executive function), quality of life, liberalization of diet, family functioning, and harms of treatment over the long term (>2years)?
In pregnant women with PKU, what is the effect of BH4 plus diet compared with placebo plus diet /standard care on Phe control, cognitive outcomes (IQ and measures of executive function), QOL, liberalization of diet, and pregnancy outcomes?
What are the components of an effective system of care for individuals with PKU?
What is the comparative effectiveness of BH4 in addition to diet, relative to diet alone, to reduce behavioral and psychological co-morbidities in individuals with PKU?
What medical supports can bring individuals with PKU back to treatment and/or dietary adherence?
Potential risk from inaction
Do interventions intended to increase adherence to diet or drug treatment in individuals with PKU lead to improved short-term and long-term cognitive outcomes? Are promotion of adherence and related positive outcomes that occur over the long term modified by important factors that include developmental stage of the individual, age, family factors, Phe level, historical adherence, and type of PKU?
In individuals with PKU not currently adherent to diet or receiving treatment for PKU, what are the effects of BH4 in promoting return to care?
In pregnant women with PKU, what is the effect of BH4 plus diet compared with placebo plus diet / standard care on Phe control, cognitive outcomes (IQ and measures of executive function), QOL, liberalization of diet, and pregnancy outcomes?
What are the components of an effective system of care for individuals with PKU?
What is the comparative effectiveness of BH4 in addition to diet, relative to diet alone, to reduce behavioral and psychological co-morbidities in individuals with PKU?
Potential to address inequities^*^
Do interventions intended to increase adherence to diet or drug treatment in individuals with PKU lead to improved short-term and long-term cognitive outcomes? Are promotion of adherence and related positive outcomes that occur over the long term modified by important factors that include developmental stage of the individual, age, family factors, Phe level, historical adherence, and type of PKU?
In children ≤4 years old with PKU, what is the effect of BH4 plus diet compared with placebo plus diet / standard care on Phe control, cognitive outcomes (IQ and measures of executive function), QOL, liberalization of diet, and growth and development?
In individuals with PKU not currently adherent to diet or receiving treatment for PKU, what are the effects of BH4 in promoting return to care?
In individuals with PKU responsive to BH4 plus diet compared with diet/standard care on outcomes including Phe control, Phe tolerance, cognitive outcomes (IQ and executive function), quality of life, liberalization of diet, family functioning, and harms of treatment over the long term (>2years)?
In individuals with PKU, what are the long-term effects (>6months) of LNAAs on cognitive outcomes (IQ and executive function), quality of life, and liberalization of diet and harms of LNAAs?
In pregnant women with PKU, what is the effect of BH4 plus diet compared with placebo plus diet /standard care on Phe control, cognitive outcomes (IQ and measures of executive function), QOL, liberalization of diet, and pregnancy outcomes?
What are the components of an effective system of care for individuals with PKU?
What harms are associated with LNAA use in individuals with PKU?
What is the comparative effectiveness of BH4 in addition to diet, relative to diet alone, to reduce behavioral and psychological co-morbidities in individuals with PKU?
What medical supports can bring individuals with PKU back to treatment and/or dietary adherence?
Potential to allow assessment of ethical, legal, social issues pertaining to the condition
Do interventions intended to increase adherence to diet or drug treatment in individuals with PKU lead to improved short-term and long-term cognitive outcomes? Are promotion of adherence and related positive outcomes that occur over the long term modified by important factors that include developmental stage of the individual, age, family factors, Phe level, historical adherence, and type of PKU?
In individuals with PKU not currently adherent to diet or receiving treatment for PKU, what are the effects of BH4 in promoting return to care?
In pregnant women with PKU, what is the effect of BH4 plus diet compared with placebo plus diet /standard care on Phe control, cognitive outcomes (IQ and measures of executive function), QOL, liberalization of diet, and pregnancy outcomes?
What are the components of an effective system of care for individuals with PKU?
What medical supports can bring individuals with PKU back to treatment and/or dietary adherence?
Potential for new knowledge
Do interventions intended to increase adherence to diet or drug treatment in individuals with PKU lead to improved short-term and long-term cognitive outcomes? Are promotion of adherence and related positive outcomes that occur over the long term modified by important factors that include developmental stage of the individual, age, family factors, Phe level, historical adherence, and type of PKU?
In children ≤4 years old with PKU, what is the effect of BH4 plus diet compared with placebo plus diet / standard care on Phe control, cognitive outcomes (IQ and measures of executive function), QOL, liberalization of diet, and growth and development?
In individuals with PKU, what are the long-term effects (>6months) of LNAAs on cognitive outcomes (IQ and executive function), quality of life, and liberalization of diet and harms of LNAAs?
In pregnant women with PKU, what is the effect of BH4 plus diet compared with placebo plus diet or /standard care on Phe control, cognitive outcomes (IQ and measures of executive function), QOL, liberalization of diet, and pregnancy outcomes?
What is the comparative effectiveness of BH4 in addition to diet, relative to diet alone, to reduce behavioral and psychological co-morbidities in individuals with PKU?

* Some questions received identical scores

Abbreviations: BH4=sapropterin dihydrochloride; IQ=intelligence quotient; LNAAs=large neutral amino acids; Phe=phenylalanine; PKU=phenylketonuria; QOL=quality of life

## Methods Questions

Table D-2 Highest ranking methods-related questions by prioritization criterion

Potential for significant health impact^*^
How can the effectiveness of combination therapies be measured?
How should registry data collection be modified to allow for collection of efficacy data?
To what degree does Phe level affect domains of social and emotional functioning in PKU?
To what extent are poor cognitive outcomes related to dietary deficiencies compared with Phe levels?
What biomarkers are valid for understanding the effects of vitamin and mineral deficiencies in PKU?
Which measures, including executive function and affective disorder screens, are shown to be associated with to changes in cognitive outcomes related to Phe level in individuals with PKU?
Potential to reduce variation in clinical practices^*^
How can the effectiveness of combination therapies be measured?
How should registry data collection be modified to allow for collection of efficacy data?
In addition to blood Phe, what measures provide valid assessments of dietary control in individuals with PKU?
To what extent are poor cognitive outcomes related to dietary deficiencies compared with Phe levels?
What biomarkers are valid for understanding the effects of vitamin and mineral deficiencies in PKU?
When measuring executive function in individuals with PKU, when and how frequently should these measures be assessed?
Potential for significant economic impact^*^
How can the effectiveness of combination therapies be measured?
How should registry data collection be modified to allow for collection of efficacy data?
To what extent are poor cognitive outcomes related to dietary deficiencies compared with Phe levels?
What is the effectiveness of spectroscopy or other imaging techniques in assessing the effects of LNAAs on neurotransmission of Phe?
What methods are effective for measuring brain amino acid absorption?
Which measures, including executive function and affective disorder screens, are shown to be associated with to changes in cognitive outcomes related to Phe level in individuals with PKU?
Potential risk from inaction
How can the effectiveness of combination therapies be measured?
How should registry data collection be modified to allow for collection of efficacy data?
To what extent are poor cognitive outcomes related to dietary deficiencies compared with Phe levels?
What biomarkers are valid for understanding the effects of vitamin and mineral deficiencies in PKU?
What is the effectiveness of spectroscopy or other imaging techniques in assessing the effects of LNAAs on neurotransmission of Phe?
Potential to address inequities
How can the effectiveness of combination therapies be measured?
How should registry data collection be modified to allow for collection of efficacy data?
In addition to blood Phe, what measures provide valid assessments of dietary control in individuals with PKU?
When measuring executive function in individuals with PKU, when and how frequently should these measures be assessed?
Which measures, including executive function and affective disorder screens, are shown to be associated with to changes in cognitive outcomes related to Phe level in individuals with PKU?
Potential to allow assessment of ethical, legal, social issues pertaining to the condition
How should registry data collection be modified to allow for collection of efficacy data?
In addition to blood Phe, what measures provide valid assessments of dietary control in individuals with PKU?
To what extent are poor cognitive outcomes related to dietary deficiencies compared with Phe levels?
What is the relationship between clinical measures of executive function and "real world"/ adaptive functioning?
When measuring executive function in individuals with PKU, when and how frequently should these measures be assessed?
Potential for new knowledge^*^
How can the effectiveness of combination therapies be measured?
How should registry data collection be modified to allow for collection of efficacy data?
In addition to blood Phe, what measures provide valid assessments of dietary control in individuals with PKU?
To what degree do measures of executive function vary with cognition, in the context of varying levels of Phe?
To what degree does Phe level affect domains of social and emotional functioning in PKU?
To what extent are poor cognitive outcomes related to dietary deficiencies compared with Phe levels?
What biomarkers are valid for understanding the effects of vitamin and mineral deficiencies in PKU?
What methods are effective for measuring brain amino acid absorption?

* Some questions received identical scores

Abbreviations: Phe=phenylalanine; PKU=phenylketonuria; QOL=quality of life