# Ongoing/Recently Completed Studies Related to Adjuvant Therapies in PKU and Ongoing Studies Search Strategies

Table B-1 Potentially relevant ongoing/recently completed studies

Table B-2 Search strategies