# Preliminary Evidence Gaps Identified From CER

## Research Questions Derived From Gaps Noted in Report by Key Question

### Key Question 1a. What is the evidence that any specific Phe levels are optimal for minimizing or avoiding cognitive impairment in individuals with PKU? Key Question 1b. What is the evidence that different target Phe levels are appropriate for minimizing or avoiding cognitive impairment for different age groups?

# | Research Questions | Potentially Relevant Ongoing Research
1 | Which domains of executive function (e.g., planning, inhibitory control) are most sensitive to changes in Phe in individuals with PKU? | None identified
2 | Which measures of executive function are shown to be associated with to changes in cognitive outcomes related to Phe level in individuals with PKU? | None identified
3 | To what degree do measures of executive function vary with cognition, in the context of varying levels of Phe? | None identified
4 | What is the validity and reliability of existing tools for measuring executive function in individuals with PKU? | None identified
5 | When measuring executive function in individuals with PKU, when and how frequently should these measures be assessed? | None identified

### Key Question 2 What is the comparative effectiveness of BH4 with dietary intervention versus dietary intervention alone for affecting outcomes including measures of cognition (including executive function), quality of life, and nutritional status?

# | Research Questions | Potentially Relevant Ongoing Research
1 | In children ≤4 years old with PKU, what is the effect of BH4 plus diet compared with placebo plus diet or standard care on Phe control, cognitive outcomes (IQ and measures of executive function), QOL, liberalization of diet, and growth and development? | - PKUDOS: Phenylketonuria (PKU) Demographic, Outcomes, and Safety Registry (NCT00778206); - Kuvan^®^ Adult Maternal Pediatric European Registry (KAMPER): Observational Study on the Long Term Safety of Kuvan^®^ Treatment in Patients With Hyperphenylalaninemia (HPA) Due to Phenylketonuria (PKU) or BH4 Deficiency (NCT01016392); - Safety, and Population Pharmacokinetics of Sapropterin Dihydrochloride (Kuvan^®^) in Phenylketonuria (PKU) Patients <4 Years Old. (SPARK) (NCT01376908); - A Phase 3b Open-Label Study to Evaluate the Effect of Kuvan® on Neurocognitive Function, Maintenance of Blood Phenylalanine Concentrations, Safety, and Population Pharmacokinetics in Young Children With Phenylketonuria (NCT00838435)
2 | In individuals with PKU responsive to BH4, what is the effect of BH4 plus diet compared with diet/standard care on outcomes including Phe control, Phe tolerance, cognitive outcomes (IQ and executive function), quality of life, liberalization of diet, and harms of treatment over the long term (>2 years)? | - PKUDOS: Phenylketonuria (PKU) Demographic, Outcomes, and Safety Registry (NCT00778206); - Kuvan® Adult Maternal Pediatric European Registry (KAMPER): Observational Study on the Long Term Safety of Kuvan® Treatment in Patients With Hyperphenylalaninemia (HPA) Due to Phenylketonuria (PKU) or BH4 Deficiency (NCT01016392)
3 | What characteristics of the individual moderate responsiveness to BH4 in individuals with PKU? | - PKUDOS: Phenylketonuria (PKU) Demographic, Outcomes, and Safety Registry (NCT00778206); - Kuvan® Adult Maternal Pediatric European Registry (KAMPER): Observational Study on the Long Term Safety of Kuvan® Treatment in Patients With Hyperphenylalaninemia (HPA) Due to Phenylketonuria (PKU) or BH4 Deficiency (NCT01016392)
4 | What is the comparative effectiveness of BH4 in addition to diet, relative to diet alone, to reduce behavioral and psychological comorbidities in individuals with PKU? | - PKUDOS: Phenylketonuria (PKU) Demographic, Outcomes, and Safety Registry (NCT00778206); - Kuvan® Adult Maternal Pediatric European Registry (KAMPER): Observational Study on the Long Term Safety of Kuvan® Treatment in Patients With Hyperphenylalaninemia (HPA) Due to Phenylketonuria (PKU) or BH4 Deficiency (NCT01016392); - A Double-blind, Placebo-controlled, Randomized Study to Evaluate the Safety and Therapeutic Effects of Sapropterin Dihydrochloride on Neuropsychiatric Symptoms in Subjects With Phenylketonuria(NCT01114737)
5 | What characteristics of the individual, including disease severity, are associated with early vs. late initial response to BH4? | - Sapropterin for treatment of patients with Phenylketonuria: Identification of subpopulations with substantial clinical benefit (Canadian Institute for Health Research—completion status not clear)

### Key Question 3 What is the comparative effectiveness of BH4 with dietary intervention versus dietary intervention alone in pregnant women with PKU for affecting outcomes in their infants, including prevention of neurological impairment, microcephaly, and cardiac defects?

# | Research Questions | Potentially Relevant Ongoing Research
1 | In pregnant women with PKU, what is the effect of BH4 plus diet compared with placebo plus diet or standard care on Phe control, cognitive outcomes (IQ and measures of executive funtion), QOL, liberalization of diet, and pregnancy outcomes? | - PKUDOS: Phenylketonuria (PKU) Demographic, Outcomes, and Safety Registry (NCT00778206); - Kuvan® Adult Maternal Pediatric European Registry (KAMPER): Observational Study on the Long Term Safety of Kuvan® Treatment in Patients With Hyperphenylalaninemia (HPA) Due to Phenylketonuria (PKU) or BH4 Deficiency (NCT01016392)
2 | What harms to the mother and offspring are associated with BH4 use in pregnant women with PKU? | - PKUDOS: Phenylketonuria (PKU) Demographic, Outcomes, and Safety Registry (NCT00778206); - Kuvan® Adult Maternal Pediatric European Registry (KAMPER): Observational Study on the Long Term Safety of Kuvan® Treatment in Patients With Hyperphenylalaninemia (HPA) Due to Phenylketonuria (PKU) or BH4 Deficiency (NCT01016392)

### Key Question 4 What is the comparative effectiveness of LNAAs with dietary intervention versus dietary intervention alone for affecting outcomes including measures of cognition (including executive function), quality of life, and nutritional status?

# | Research Questions | Potentially Relevant Ongoing Research
1 | In individuals with PKU, what are the long-term effects (>6 months) of LNAAs on Phe control, Phe tolerance, cognitive outcomes (IQ and executive function), quality of life, and liberalization of diet and harms of LNAAs? | - Effects of short term increase of phenylalanine levels on neuropsychological functions and well-being in adults with phenylketonuria: the “diet for life” study- supplement of amino acids (NTR1056)
2 | What harms are associated with LNAA use in individuals with PKU? | - Effects of short term increase of phenylalanine levels on neuropsychological functions and well-being in adults with phenylketonuria: the “diet for life” study- supplement of amino acids (NTR1056)

### Key Question 7 What is the evidence for the effectiveness of the addition of BH4 or LNAAs to dietary intervention for affecting outcomes in subgroups of patients?

# | Research Questions | Potentially Relevant Ongoing Research
1 | What are short-term effects of BH4 on outcomes including Phe control, Phe tolerance, cognitive outcomes (IQ and executive function), quality of life, and liberalization of diet, and harms of BH4 in specific subgroups (defined by age, dietary control, disease type)? | - PKUDOS: Phenylketonuria (PKU) Demographic, Outcomes, and Safety Registry (NCT00778206); - Kuvan® Adult Maternal Pediatric European Registry (KAMPER): Observational Study on the Long Term Safety of Kuvan® Treatment in Patients With Hyperphenylalaninemia (HPA) Due to Phenylketonuria (PKU) or BH4 Deficiency (NCT01016392); - Effects of Sapropterin on Brain and Cognition in Individuals With Phenylketonuria (NCT00730080); - Evaluation of Behavior, Executive Function, Neurotransmitter Function and Genomic Expression in PKU “Nonresponders” to Kuvan(NCT01274026); - Treatment of hyperphenylalaninemia with Sapropterin dihydrochloride (tetrahydrobiopterin, 6R-BH4) and its influence on the amino acids and fatty acids patterns from childhood to adulthood, a Phase IV, longitudinal, unblinded, controlled, single-centre, retrospective and prospective clinical study(ISRCTN77098312)

## Overall/Foundational Questions

# | Research Question | Potentially Relevant ongoing Studies
1 | Among individuals with PKU using pharmacologic therapy, are supportive adherence models effective in increasing adherence? | None identified
2 | Are supportive adherence models effective at improving long-term cognitive outcomes? | None identified
3 | Among effective adherence support systems, have individual components been shown to drive effectiveness? | None identified
4 | Is the effectiveness of adherence models moderated by characteristics of the individual, including age, gender, family structure and severity of disease? | None identified
5 | What are the pharmacokinetic, pharmacodynamic, and pharmacogenomic factors associated with treatment response in individuals with PKU? | None identified
6 | Are passive registries as effective as ongoing cohort studies for collecting adequate data to assess long-term effectiveness of adjuvant therapies? | - PKUDOS: Phenylketonuria (PKU) Demographic, Outcomes, and Safety Registry (NCT00778206); - Kuvan® Adult Maternal Pediatric European Registry (KAMPER): Observational Study on the Long Term Safety of Kuvan® Treatment in Patients With Hyperphenylalaninemia (HPA) Due to Phenylketonuria (PKU) or BH4 Deficiency (NCT01016392)
7 | In addition to blood Phe, what measures provide valid assessments of dietary control in individuals with PKU? | - PKUDOS: Phenylketonuria (PKU) Demographic, Outcomes, and Safety Registry (NCT00778206); - Kuvan® Adult Maternal Pediatric European Registry (KAMPER): Observational Study on the Long Term Safety of Kuvan® Treatment in Patients With Hyperphenylalaninemia (HPA) Due to Phenylketonuria (PKU) or BH4 Deficiency (NCT01016392)
8 | What are the components of an effective system of care for individuals with PKU? | None identified
9 | What treatment-related factors at different ages are the greatest source of concern to families/caregivers? | - 5-year Follow-up of the Comparison of Life and Physical Health in Adult Patients With PKU and Healthy Age Matched Controls (NCT01096758)
10 | In individuals with PKU, what timing of Phe monitoring is optimal for fine tuning diet and treatment? | - The effects of online availability of individual phenylalanine levels to patients with phenylketonuria (NTR1171)

Additional (nonresearch) recommendations/needs:

- Increased understanding of long-term implications of intermediate outcomes
- Multi-collaborator consortium that includes a public-private partners to outline research agenda; evaluate needs for comprehensive system of care; develop/expand prospective registries to include collection of outcome data including measures of executive function, nutritional status, growth, and quality of life; and biorepository
- Understanding of the role of international collaboration and differences in diet, culture, genotype/phenotype, etc. in planning for multicenter consortia
- Standardized data collection tools, especially for cognitive outcomes
- Standards/guidelines for data sharing and comprehensive reporting (including reporting of measures of variance, potential cofounding and modifying factors, etc.)
- Standardized collection and reporting of potential confounders and modifiers (e.g., familial IQ, SES, maternal education, concurrent medications, age at initial treatment, level of dietary control)
- Increased understanding of outcomes of importance to patients and families
- Understanding of quality of life for patients and families and factors that affect quality of life
- Understanding approaches to studying adjuvant therapies in pregnant women with PKU (e.g., registry, cohort study)
- Understanding of study designs that can provide high-quality data while taking into account difficulties in accrual in rare diseases
- Studies appropriately designed and powered to allow subgroup analyses
- Understanding of the potential role of observational studies in providing effectiveness data
- Publicly funded studies
- Understanding of potentially useful research models from other rare disease