# Abbreviations

ADHD: Attention Deficit Hyperactivity Disorder
AHRQ: Agency for Healthcare and Research Quality
BH4: Sapropterin Dihydrochloride
CER: Comparative Effectiveness Review
EHC: Effective Health Care Program
EPC: Evidence-based Practice Center
FDA: Food and Drug Administration
HPA: Hyperphenylalaninemia
IQ: Intelligence Quotient
KAMPER: Kuvan^®^ Adult Maternal Pediatric European Registry
LNAA: Large Neutral Amino Acids
N: Number
Phe: Phenylalanine
PICOTS: Population-Intervention-Comparators-Outcomes-Timing-Setting
PKU: Phenylketonuria
PKUDOS: Phenylketonuria Demographic, Outcomes, and Safety Registry
NIH: National Institutes of Health
QOL: Quality of Life
RCT: Randomized Controlled Trial
SER: Systematic Evidence Review
SOE: Strength of Evidence
SPARK: Safety, and Population Pharmacokinetics of Sapropterin Dihydrochloride (Kuvan^®^)
TEP: Technical Expert Panel
TOO: Task Order Officer