# Results

## Research Needs

In the draft review we identified significant gaps in the research literature addressing adolescents and young adults with ASD. We then developed the list of preliminary evidence gaps into research questions (Table 2) and methodologic recommendations (Table 3), based on information from the draft review and input from our stakeholders.

Table 2 Snowballed list of research questions

Number | Research Questions
1 | What is the validity of best available quality of life measurements across adolescents and young adults with ASD? Examination of measures in comparison to objective metrics (educational, occupational, developmental milestone), self-determined outcomes, and family based outcomes.
2 | What is the impact of common social and behavioral interventions in combination/comparison with pharmacological paradigms aimed at enhanced social learning on core symptoms?
3 | What is the impact of augmentative communication and novel technological paradigms for individuals with severe communication impairments at specific developmental target ranges (e.g., nonverbal, comorbid intellectual disability, adolescents)?
4 | What is the effectiveness of comprehensive and intensive treatment approaches (specific educational, residential, intensive work programs) in adolescents with ASD for ameliorating core symptoms?
5 | What is the effectiveness of interventions implemented in the community compared to the research setting among adolescents and young adults with ASD?
6 | What is the effectiveness of paradigms and combinations of paradigms currently used in community based programs for adolescents and young adults with ASD?
7 | What is the impact of common behavioral interventions (manualized CBT and familial treatment paradigms on anxiety/depression) treating psychiatric comorbidities in non-ASD samples in combination/comparison with pharmacological paradigms aimed at treating comorbidities.
8 | What is the effectiveness of available interventions for treating behavioral issues including sudden aggression and catatonia during transition years in adolescents and young adults with ASD?
9 | What is the effectiveness of available transition programs (e.g., work readiness programs, community programs, vocational programs, private ABA schools, CBT programs, social skills training and programs, person-centered planning) in ASD?
10 | What are appropriately sensitive metrics of quality of life, functional outcome, and how does that overlay with the heterogeneous range of characteristics of individuals, families, and systems in ASD?
11 | What is the impact on the most common transition programs across individual, familial, and more broadly defined outcomes?
12 | What is the effectiveness of interventions designed to support goals toward life satisfaction for adolescents and young adults with ASD and family members?
13 | What is the impact of interventions on stress levels for family members and adolescents and young adults with ASD?
14 | What is the effectiveness of systems level interventions specific to the legal system in managing adolescents and young adults with ASD?
15 | To what extent does participation in services and potential dependency on services lead to declining ability to function independently in adolescents and young adults with ASD?
16 | What is the effectiveness of early intervention programs to improve functional behavior in adolescents and young adults with ASD?

ASD = autism spectrum disorders; CBT = cognitive behavior therapy; ABA = applied behavioral analysis

Table 3 Snowballed list of methodologic recommendations

Number | Methodologic Recommendations
1 | What measurable characteristics (individual, familial, system) predict successful transition from supportive educational settings?
2 | What is the validity of best available existing psychiatric comorbidity measurements across adolescents and young adults with ASD?
3 | What measurable psychiatric and medical comorbidities predict less successful transition from supportive educational settings as well as impact quality of life metrics?
4 | What is the validity of standard measurements for assessing mental health in adolescents and young adults with ASD?
5 | What is the utility of measures developed for nonautistic individuals with mental health disorders in adolescents and young adults with ASD with mental health comorbidities?
6 | How can the trajectory of comorbidities in adolescents and young adults with ASD be measured over the lifespan?
7 | What is the impact of comorbidities on family life over the lifespan?
8 | What measurable characteristics (individual, familial, system) predict successful transition from supportive educational settings?
9 | What are the measurable characteristics that determine a satisfying quality of life for adolescents and young adults with ASD?
10 | Explicit inclusion markers of broadly defined harm, adverse event, distress/impact across defined intervention studies above.
11 | Explicit inclusion markers of broadly defined measures of family impact in studies above.

ASD = autism spectrum disorders

We also identified a number of nonresearch issues/recommendations from the full report and stakeholder feedback (Table 4) that are fundamental study designs and outcome measurement issues, which fell outside the scope of the future research needs project’s focus. These questions were not included in the prioritization surveys but are important to address in additional research.

Table 4 Nonresearch recommendations/needs identified in CER and by stakeholders

1 | Need for pragmatic trials that look at interventions as they actually occur.
2 | Need to develop studies that are adequately powered and designed to capture the moderator information.
3 | Need measures to define quality of life beyond good or poor outcomes, work status, relationship status, and how to measure quality of life across the research base.
4 | Need tools/measurements to assess harms throughout the intervention regarding patient satisfaction (e.g. happiness, quality of life measures) and stress.
5 | Need to develop studies that look at prevention of wandering and elopement during transitional years in adolescent and young adults with ASD
6 | Systems-level measures need to be developed to measure outcomes of adolescents and young adults with ASD, including family outcomes. Outcomes need to include the family as a usual element of studies of adolescents and young adults with ASD.
7 | Need to compare caretaker burden in other disease conditions (i.e., Alzheimer’s) and the effect it has on family members, spouse and children, and other relatives.

ASD = autism spectrum disorders

## Round One Prioritization

In the first prioritization (round one) survey, stakeholders prioritized needs by allotting a limited number of points (18 points for 27 questions/needs) to the questions. Six out of seven stakeholders completed the survey. The highest priority questions (questions scoring at least 5 points, n = 12/27) identified via the round one survey are organized below by broad area of focus. Twelve research questions received five or more votes, and were considered the top tier after the first prioritization round. Of these, seven were treatment questions and five were methodologic questions. The remaining lower tier questions with four or fewer votes did not advance to the final prioritization round, listed in Appendix F. The top seven treatment questions were the following:

1. What is the effectiveness of available transition programs (e.g., work readiness programs, community programs, vocational programs, private ABA schools, Cognitive Behavior Therapy (CBT) programs, social skills training and programs, person-centered planning) in ASD?
2. What is the impact on the most common transition programs across individual, familial, and more broadly defined outcomes?
3. What is the effectiveness of interventions designed to support goals toward life satisfaction for adolescents and young adults with ASD and family members?
4. What is the effectiveness of early intervention programs to improve functional behavior in adolescents and young adults with ASD?
5. What is the impact of common behavioral interventions (manualized CBT and familial treatment paradigms on anxiety/depression) treating psychiatric comorbidities in non-ASD samples in combination/comparison with pharmacological paradigms aimed at treating comorbidities?
6. What is the effectiveness of paradigms and combinations of paradigms currently used in community based programs for adolescents and young adults with ASD?
7. What are appropriately sensitive metrics of quality of life, functional outcome, and how does that overlay with the heterogeneous range of characteristics of individuals, families, and systems in ASD?

The top five methodologic questions were:

8 What measurable characteristics (individual, familial, system) predict successful transition from supportive educational settings?
9 What is the validity of best available existing psychiatric comorbidity measurements across adolescents and young adults with ASD?
10 What measurable psychiatric and medical comorbidities predict less successful transition from supportive educational settings as well as impact quality of life metrics?
11 What are the measurable characteristics that determine a satisfying quality of life for adolescents and young adults with ASD?
12 How can the trajectory of comorbidities in adolescents and young adults with ASD be measured over the lifespan?

## Round Two Prioritization

We asked stakeholders to prioritize each of the 12 high priority research questions using the modified Effective Health Care Program selection criteria (PiCMe) using a 1(low) to 5 (high) point scale:

- Potential for significant health impact
- Potential to reduce variation in clinical practices
- Potential for significant economic impact
- Potential risk from inaction
- Potential to address inequities
- Potential to allow assessment of ethical, legal, social issues pertaining to the condition
- Potential for new knowledge

Six out of seven stakeholders completed the survey. We tallied the scores for each question on each criterion to determine on overall score (Appendix H) and considered questions by a range of scores into top, middle, and lower tiers (Table 5). The top priority future research needs are listed below with PICOTS elements and study design considerations that were identified by the EPC team. Each question in the top tier is considered to be of equal importance; the order is not an indication of ranking.

Table 5 Top-tier treatment-related research questions with detail

Research Question | Tier | Relevant PICOTS Area(s) | Study Design Comments/Suggestions
What is the effectiveness of available interventions for treating behavioral issues (e.g., aggression, self-injury, and other challenging behaviors) during transition years in adolescents and young adults with ASD? | Top | Population: Adolescents and young adults with ASD Intervention: Manualized ABA-based interventions Comparators: Drug + ABA Drug + Manualized psychotherapy Manualized psychotherapy Outcomes: Measures of health care utilization, hospitalization, and psychotropic drug use; Family functioning Timing: 16 weeks + followup | Appropriate control groups are essential and interventions should be manualized to allow replication.
What is the effectiveness of early intervention programs to improve functional behavior in adolescents and young adults with ASD? | Top | Population: Children, adolescents and young adults with ASD Intervention: ABA-based interventions in early childhood Comparators: Community based services Outcomes: Improvement of functional behavior over long periods of time into adolescence and adulthood | Prospective studies are needed, despite the challenge of following children through childhood and adolescence. Randomization may be impossible so ascertainment and control for confounding variables is especially important.
What is the effectiveness of available manualized transition programs (e.g., work readiness programs, vocational programs, person-centered planning, training programs) in ASD? | Top | Population: Adolescents and young adults with ASD Intervention: Manualized transition programs(e.g., work readiness programs, vocational programs, person-centered planning, training programs) Comparators: No participation in transition programs or other types of transition programs Outcomes: Hours out of the home (e.g., volunteering, working) to measure behavioral flexibility; Functional engagement; Family hours working/increase in income | Randomization is ideal, or very good characterization of participants for analysis. Investigators need ways to identify the “active ingredient” in these interventions, and should report longer term outcomes and outcomes other than simply having employment.
What is the effectiveness of community based programs (e.g., private ABA schools, CBT programs, social skills programs) to provide care for adolescents and young adults with ASD? | Top | Population: Adolescents and young adults with ASD Intervention: Community based programs (e.g., private ABA schools, CBT programs, social skills programs) Comparators: No participation in community-based programs or other types of community-based programs Outcomes: Measures of social engagement; participation in external activities Setting: School based, community based | Randomization is ideal, or very good characterization of participants for analysis. Investigators need ways to identify the “active ingredient” in these interventions, and should report participant-centered outcomes.

ASD = autism spectrum disorders; ABA = applied behavioral analysis; CBT = cognitive behavior therapy

## Study Design Considerations for Top-Tier Research Needs

### What is the effectiveness of available interventions for treating behavioral issues (e.g., aggression, self-injury, and other challenging behaviors) during transition years in adolescents and young adults with ASD?

Challenging behaviors are relatively common among adolescents and young adults with ASD, and the presence of severe behavior problems limits the ability of these individuals to find employment (supported or otherwise) in the community.12 Thus, interventions aimed at reducing behavioral issues might increase transition success for young adults with ASD.

Research is needed to examine the effectiveness of interventions for treating behavioral issues in adolescents and young adults with ASD. Some of these interventions have been tested with school-age children, and their effects may or may not generalize to this older age range. Researchers interested in addressing this question will want to pay attention to the feasibility of the behavioral interventions for young adults, in particular. If the intervention is delivered to younger children in a school setting, finding an appropriate out-of-home setting to deliver the intervention to young adults might prove to be a challenge. This is because young adults with ASD participate in a vast array of educational and vocational activities, from segregated vocational placements to independent jobs in the community. Further, many young adults with ASD have no educational or vocational activities after leaving high school.12, 13 Similarly, interventions that are delivered in home to children with ASD might need to be adapted for young adults with ASD who no longer live in the parental home.

Investigators will also want to be sure to include an appropriate comparison group to test this question, ideally with random assignment to treatment and control. This is particularly important because autism symptoms and problem behaviors improve over adolescence and adulthood for many individuals with ASD.3, 10 Without a control group, it will be impossible to determine whether improvements in problem behaviors are a result of intervention or maturation. Finally, it is important that studied interventions are manualized, which will allow for replication and implementation in other samples.

### What is the effectiveness of early intervention programs to improve functional behavior in adolescents and young adults with ASD?

With intensive early intervention becoming a relatively common treatment approach for children with ASD and their families, research should address whether these programs have long-lasting effects. That is, do early intervention programs improve functional behavior and transition outcomes for adolescents and young adults with ASD?

Although this is an important research question, there are three major challenges that would be faced by researchers. First, it would be best to follow children from the time of diagnosis and early intervention through adolescence and young adulthood. Asking parents of young adults to retrospectively recall detailed information about early intervention programs would likely lead to inaccuracies. Second, random assignment to different types of early intervention programs will be difficult, as the types of programs available differ by region and withholding potentially beneficial intervention might be seen as unethical. Thus, researchers will likely have to contend with demographic or other differences between families who do and do not have access to early intervention, making it difficult to determine whether the intervention itself is the “active ingredient” in differences observed in young adult outcomes. For example, families with more economic resources may be more likely to get more intensive early intervention, but these same economic resources may provide additional opportunities for a young adult with ASD.14, 15 Thus, economic resources would be the “active ingredient” and not the intervention per se. Even with random assignment, given the heterogeneity in early intervention programs (type of program, number of hours administered, etc.), as well as the many other possible services and therapies accessed by families of children with ASD (e.g., speech therapy; special diets, varying amounts of additional supports in schools, etc.), it may be difficult to isolate the long-term impact of the early intervention itself.

### What is the effectiveness of available manualized transition programs (e.g., work readiness programs, vocational programs, person-centered planning, and training programs) in ASD?

Perhaps the key consideration for researchers who are interested in testing the effectiveness of manualized transition programs is the inclusion of an appropriate control or comparison group, ideally with random assignment. As revealed in our draft report, no studies of vocational programs utilized random assignment. In many cases, there were characteristics of adults with ASD that were conducive to employment, which were used to assign them to the intervention (vs. comparison) group. Thus, there were differences between the intervention and comparison groups to start out with, making it difficult to determine whether observed effects of the program were a result of the program itself.

Researchers should also consider the long-term effects of the transition programs. Do any observed gains continue after the program is terminated? The most effective interventions will result in gains that are maintained even after the intervention is completed. Perhaps the most significant challenge facing researchers interested in this question is discovering which aspect of the transition program is the “active ingredient.” Manualized transition programs are often multifaceted, recognizing the many different skills that need to be taught or the many different pieces that need to come together for youth with ASD to successfully transition.11 Determining the most effective aspect of the program will be difficult, but is necessary to design maximally effective programs with little waste.

### What is the effectiveness of paradigms and combinations of paradigms currently used in community-based programs (e.g., private ABA schools, CBT programs, social skills programs) to provide care for adolescents and young adults with ASD?

As described above, a key consideration for this research question will be the identification of an appropriate comparison group. Equivalence in terms of presentation of ASD, as well as clinical and psychiatric comorbidities will either need to be achieved in the design or managed in the analysis of these types of interventions. It will also be challenging to isolate the effects of the interventions themselves beyond other care and supports that are being provided to the adolescent. It would be further helpful to characterize the families and communities in which the adolescents reside to identify potential modifiers of effectiveness in terms of family dynamics or community characteristics. The intervention programs themselves will need to be fully described, and ideally, manualized. As we have noted in previous work, detail is often lacking on treatment programs to allow investigators to understand the outcomes they are observing. A range of outcomes will be important, including measures of individual and community engagement, and it would be helpful to understand the impact of these interventions on educational and vocational attainment.

### Remaining Study Design Questions

The remaining study design considerations identified by the stakeholders listed in Table 6 were not considered highest priority. The low priority intervention studies center around the issues of common behavioral interventions treating psychiatric comorbidities and interventions to support goals toward life satisfaction for individuals with ASD and family members.

Table 6 Lower priority intervention studies

Question/Need | Tier
What is the impact of common behavioral interventions (manualized CBT and familial treatment paradigms on anxiety/depression) treating psychiatric comorbidities in non-ASD samples in combination/comparison with pharmacological paradigms aimed at treating comorbidities? | Low
What is the effectiveness of interventions designed to support goals toward life satisfaction for adolescents and young adults with ASD and family members? | Low

CBT = cognitive behavior therapy; ASD = autism spectrum disorders

## Study Design Considerations for Methods Questions and Foundational Research

The lack of evidence for the effectiveness of treatments for adolescents and young adults with ASD identified in our draft report is indicative of a more general paucity of research focused on individuals with ASD in this age range. That is, there are also very few studies of the natural history of individuals with ASD as they transition to adulthood. This foundational research is necessary as it would provide an understanding of the range of transition outcomes experienced by youth with ASD, as well as the factors that might promote successful outcomes. Without this work, it becomes nearly impossible to conceptualize and design maximally effect treatments and interventions. Below, we summarize some of the key methodological and foundational research needs identified by our stakeholders and necessary to inform treatments for adolescents and young adults with ASD. One foundational question was ranked in the highest priority tier (Table 7).

Table 7 Top-tier methods questions/foundational research

Methods/Other Related Research Questions | Tier
What measurable psychiatric and medical comorbidities predict less successful transition from supportive educational settings as well as affect quality of life metrics? | Top

### What measurable psychiatric and medical comorbidities predict less successful transition from supportive educational settings as well as affect quality of life metrics?

Psychiatric and medical comorbidities are extremely common in adolescents and young adults with ASD, and likely affect their ability to successfully transition out of high school and into the adult world. In order to understand which comorbidities should be the target of intervention (e.g., anxiety; seizures; gastrointestinal issues), descriptive foundational research is necessary to determine which comorbidities seem to be most associated with transition problems.

In order to best answer this question, youth with ASD will need to be followed prospectively, starting during adolescence and continuing through the transition years and beyond. Retrospective research should be avoided, as it would be difficult to determine whether medical and psychiatric comorbidities predicted transition difficulties or whether they emerged concomitantly with or after the youth with ASD had transitioned. This is especially important because some mental health comorbidities often do not emerge until early adulthood. Finally, because any given comorbidity is relatively rare (although comorbidities as a group are common among youth with ASD), examining the differential effects of individual comorbidities will necessitate a relatively large sample size.

### Remaining Methods/Foundational Questions

The remaining methods questions and foundational research needs (Table 8) identified by the stakeholders, but not considered the highest priority, center around the issue of measurement.

Table 8 Middle- and low-tier methods/foundational research

Question/Need | Tier
What measurable characteristics (individual, familial, system) predict successful transition from supportive educational settings? | Middle
What are the measurable characteristics that determine a satisfying quality of life for adolescents and young adults with ASD? | Middle
How can the trajectory of comorbidities in adolescents and young adults with ASD be measured over the lifespan? | Middle
What is the validity of best available existing psychiatric comorbidity measurements across adolescents and young adults with ASD? | Low
What are appropriately sensitive metrics of quality of life, functional outcome, and how does that overlay with the heterogeneous range of characteristics of individuals, families, and systems in ASD? | Low

ASD = autism spectrum disorders

First, research is needed to understand how best to conceptualize and measure psychiatric comorbidities among adolescents and young adults with ASD. Although there are many different, well-validated ways to measure psychiatric disorders in adolescents and adults who do not have ASD—including both questionnaires and clinical interviews it is unclear how well these existing measures capture psychiatric comorbidities among individuals with ASD. Thus, our ability to measure the emergence of comorbidities in these adolescents and young adults, as well as whether treatments can impact comorbidities, are constrained by the lack of well-validated outcome measures.

Second, research on treatments for adolescents and adults with ASD are constrained by the lack of agreement on what should be considered a “good” outcome and thus the target of intervention. Although many natural history studies focus on competitive employment and independent living as key indicators of good transition outcomes, these measures clearly disadvantage those individuals with greater impairments and greater support needs. Given the vast heterogeneity in characteristics of young adults with ASD, sensitive metrics should be developed and tested that can capture aspects of a positive transition other than just objective living and working arrangements. Examples might be the development of quality of life measures or measurement of the goodness of fit between the environment of the young adult with ASD and his/her needs and interests.16 Another possible metric might be reduction in challenging behaviors or the addition of functional skills during the transition time.