# References

1 Autism and Developmental Disabilities Monitoring Network Surveillance Year 2008 Principal Investigators; Centers for Disease Control and Prevention, et al. Prevalence of autism spectrum disorders—Autism and Developmental Disabilities Monitoring Network, 14 sites, United States, 2008. MMWR Surveill Summ. Mar. 30. 2012;61(3):1-19. [pmid: 22456193].
2 Fombonne E. Epidemiological surveys of autism and other pervasive developmental disorders: an update. J Autism Dev Disord. Aug. 2003;33(4):365-82. [pmid: 12959416].
3 Shattuck PT, Seltzer MM, Greenberg JS, et al. Change in autism symptoms and maladaptive behaviors in adolescents and adults with an autism spectrum disorder. J Autism Dev Disord. Oct. 2007;37(9):1735-47. [pmid: 17146700].
4 McGovern CW, Sigman M. Continuity and change from early childhood to adolescence in autism. J Child Psychol Psychiatry. Apr. 2005;46(4):401-8. [pmid: 15819649].
5 Fecteau S, Mottron L, Berthiaume C, et al. Developmental changes of autistic symptoms. Autism. Sep. 2003;7(3):255-68. [pmid: 14516059].
6 Seltzer MM, Krauss MW, Shattuck PT, et al. The symptoms of autism spectrum disorders in adolescence and adulthood. J Autism Dev Disord. Dec. 2003;33(6):565-81. [pmid: 14714927].
7 Seltzer MM, Shattuck P, Abbeduto L, et al. Trajectory of development in adolescents and adults with autism. Ment Retard Dev Disabil Res Rev. 2004;10(4):234-47. [pmid: 15666341].
8 Schall C, McDonough J. Autism spectrum disorderes in adolescence and early adulthood: characteristics and issues. J Vocat Rehabil. 2010;32:81-8.
9 Harmon A. Autistic and Seeking a Place in an Adult World. New York Times. 2011. Sept. 17. Available at: http://www.nytimes.com/2011/09/18/us/autistic-and-seeking-a-place-in-an-adult-world.html?pagewanted=all.
10 Taylor JL, Seltzer MM. Changes in the autism behavioral phenotype during the transition to adulthood. J Autism Dev Disord. Dec. 2010;40(12):1431-46. [pmid: 20361245].
11 Howlin P, Alcock J, Burkin C. An 8 year follow-up of a specialist supported employment service for high-ability adults with autism or Asperger syndrome. Autism. Dec. 2005;9(5):533-49. [pmid: 16287704].
12 Taylor JL, Seltzer MM. Employment and post-secondary educational activities for young adults with autism spectrum disorders during the transition to adulthood. J Autism Dev Disord. May. 2011;41(5):566-74. [pmid: 20640591].
13 Shattuck PT, Narendorf SC, Cooper B, et al. Postsecondary education and employment among youth with an autism spectrum disorder. Pediatrics. Jun. 2012;129(6):1042-9. [pmid: 22585766].
14 Mandell DS, Morales KH, Xie M, et al. Age of diagnosis among Medicaid-enrolled children with autism, 2001–2004. Psychiatr Serv. Aug. 2010;61(8):822-9. [pmid: 20675842].
15 Shattuck PT, Wagner M, Narendorf S, et al. Post-high school service use among young adults with an autism spectrum disorder. Arch Pediatr Adolesc Med. Feb. 2011;165(2):141-6. [pmid: 21300654].
16 Henninger NA, Taylor JL. Outcomes in adults with autism spectrum disorders: a historical perspective. Autism. (in press).