# Methods

## Identification of Evidence Gaps

We developed the preliminary evidence gaps identified in the report into research questions, with input from our EPC team content experts, and stakeholder contribution during a teleconference call and online snowballing survey. The snowball survey allowed us to solicit additional comments and questions after the teleconference call. We reviewed stakeholder responses from the teleconference call and snowball survey, and developed a refined list of research questions. We compiled the gaps that fell outside of our scope of research gaps/methods related to therapies for adolescents and young adults with ASD into Appendix A. We did not ask stakeholders to prioritize these out-of-scope needs. Methods for developing future research needs are listed in Table 1 and expand on the table’s brief description in each of the following sections.

Table 1 Methods for developing future research needs

Approach to Evidence Gap Identification | 1 Generate preliminary list of research gaps related to interventions for adolescents and young adults with ASD based on the gaps noted in the CER; 2 Form stakeholder workgroup with representatives from groups including patient/family/advocacy organizations, the provider community, the research community, and funding agencies; 3 Locate ongoing trials and other funded research; 4 Conduct conference call with stakeholders to refine initial list of evidence gaps; 5 Review teleconference responses and refine list of research gaps related to interventions for adolescents and young adults with ASD
Approach to Prioritization and Stakeholder Engagement for Prioritization | 6 Request that stakeholders prioritize research gaps; 7 Cull list of prioritized gaps to top tier research needs based on stakeholder voting; 8 Request that stakeholders assess top priority needs using modified EHC selection criteria
Approach to Research Question Development and Considerations for Potential Research Designs | 9 Determine potential study designs to address final list of research needs; 10 Develop research needs report; 11 Request stakeholder input on the draft research needs report; 12 Finalize research needs report

CER = comparative effectiveness review; EHC = Effective Health Care Program; ASD = autism spectrum disorders

## Criteria for Prioritization

We identified stakeholders from multiple areas of expertise (clinical, behavioral, psychopharmacological, parents/advocates) to help ensure broad representation of viewpoints. Each stakeholder submitted conflict of interest documentation and curriculum vitae that were approved by the Agency for Healthcare Research and Quality (AHRQ) Task Order Officer (TOO). We conducted one conference call with stakeholders to refine the preliminary list of research questions by KQ. We sent out a snowball survey by email to solicit additional comments after the teleconference call. We reviewed the stakeholder responses and developed a comprehensive list of research questions related to therapies for adolescents and young adults with ASD after reviewing the teleconference responses and snowball survey.

We then developed two self-administered, Web-based research prioritization questionnaires. The first round prioritization allowed the stakeholders to identify an initial set of priority questions by allotting 18 votes across the 27 questions.

We asked stakeholders to consider overall importance of the question for interventions for adolescents and young adults with ASD but did not proscribe specific criteria for prioritizing at this phase. We limited the number of votes available to roughly two-thirds of the number of questions identified to ensure that stakeholders selected high priority issues. We then compiled votes across stakeholders and questions to determine the top tier research needs. We determined that the cutoff for top tier and bottom tier was five or more votes allotted to each individual question. By using this criterion, we were able to move forward 12 questions to the next prioritization round for further ranking by Effective Health Care criteria. The second and final prioritization survey allowed the stakeholders to further prioritize the questions using the criteria developed in the Prioritization Criteria Methods (PiCMe; Appendix B) approach to prioritization:

- Potential for significant health impact
- Potential to reduce variation in clinical practices
- Potential for significant economic impact
- Potential risk from inaction
- Potential to address inequities
- Potential to allow assessment of ethical, legal, social issues pertaining to the condition
- Potential for new knowledge

Stakeholders ranked each question on each of the criteria using a 1 (low) to 5 (high) point scale.

## Identification of Ongoing Research

We reviewed ongoing or recently completed studies related to adolescents and young adults with ASD since the draft of the evidence review in 2012, through a search of clinical trial registries, grant databases, and individual funders’ Web sites (Appendix C). All current and ongoing research was searched between March 13 and March 21, 2012. We found 111 current or recent studies on ClinicalTrials.gov, of which 72 were drug therapy studies, 14 were behavioral studies, 9 were on dietary or supplement-based studies, and 3 were studies in complementary and alternative medicine. Most of the ongoing studies included children and/or adults and were not specific to adolescents and young adults (ages 13 to 30).

We found six unique trials through Center Watch, a Web-based resource that catalogues clinical trials. Three were drug therapy studies, two were assessment related, and one did not list any intervention specifics. We search the National Institute of Health Reporter and located four therapy trials addressing language learning skills, cognitive enhancement therapy, school/community-based intervention for social skills, and an employment skills program. We also searched Autism Speaks Clinical Trials Network and found trials on memantine and flouxetine drug therapies. We searched Autism Speaks Grant Database and retrieved 156 grants from 2006 to present. We were not able to parse out age groups for this database.

## Engagement of Stakeholders, Researchers, and Funders

Stakeholders were emailed an invitation with followup reminder emails as needed. The email invitation included an overview of our project, what their participation would entail, and contact information should they have any questions. Once they indicated willingness to participate, a member of our research team responded with potential times for the teleconference call. Stakeholders were informed that the project would involve participation in an initial 60-minute teleconference call, followed by a snowball survey to gather additional research questions, and two rounds of prioritization to vote on the selected future research questions.

We initially invited 19 potential stakeholders to participate in our multistep process for identifying and prioritizing future research needs for interventions for adolescents and young adults with ASD. Of the 19 invited, 7 stakeholders agreed to participate, and none declared significant conflicts of financial or professional/business interests. Stakeholders unable to participate did not provide reasons for not participating. We identified stakeholders from multiple areas of expertise (clinical, psychopharmacological, behavioral, parents/advocates) to help ensure broad representation of viewpoints. The AHRQ TOO reviewed all disclosures and identified no conflicts of interest that precluded participation in the project. Stakeholders were informed that they were not required to participate in all components of the multistep process.

To increase our understanding of the most critical research gaps, we conducted a teleconference call with five out of the seven stakeholders (two had time conflicts). The teleconference call was open-ended and elicited stakeholder perspectives on priority areas related to future research on interventions for adolescents and young adults with ASD. We emailed each stakeholder an electronic copy of the executive summary of the draft review and a list of identified potential research questions prior to the teleconference call. At the beginning of the call, the lead investigator reiterated the overall findings of the draft evidence review and the scope of the future research needs project. The teleconference format was intentionally open ended to allow stakeholders time to ask clarifying questions and to influence the direction of the conversations. We were mindful throughout to emphasize our goal of identifying areas of research that were relevant within the scope of the KQs from the evidence review. At the end of the teleconference call, we described the next steps that included snowballing and two prioritization surveys.

During the teleconference call, we elicited stakeholder opinions on where uncertainties in care decisions existed as well as what fundamental questions remained unanswered regarding transition of adolescents with ASD to adulthood. The research questions identified focused on topics such as strategies for transition and support programs for adolescents; predictors of successful transition; quality of life measurements for the individual and family members; interventions implemented in the community; assessment of comorbidities during adolescent and transition years; evaluation of programs (e.g., vocational, work readiness, community, transitional); and harms related to intervention programs (nonmedical).

Prior to the prioritization rounds, we sent out a snowball survey through email to elicit any additional feedback/comments and additional questions to add to the initial list of research gaps. The snowball survey was sent in the form of an email and attachment (Appendix D) and was available for comment from May 17 to May 23, 2011. The purpose of the snowball survey was to allow stakeholders an additional chance to comment and make contributions to the existing list of research gaps.

We developed two Web-based research prioritization surveys: one to identify an initial set of top priorities (Appendix E), and a final prioritization survey to rank the top-tier highest priority research areas. The first prioritization survey included the 27 identified research needs from the draft review, stakeholder teleconference call and snowball round. We tested the initial questionnaire to assess comprehensiveness and usability of the instrument.

The first round of prioritization was conducted using self-administered Web-based prioritization software developed by the University of North Carolina Sheps Center. Up to two reminders were sent by email to remind participants to complete the survey. The first prioritization round survey consisted of 27 research gaps in the form of a research question related to the KQs from the draft evidence review, to identify priority research topics. The first prioritization survey was open from May 25 to June 5, 2012. For each of the identified research questions, stakeholders were asked to rank the question from 1 to 5; low to high priority for future research, and to provide any additional comments on the existing list of questions. Stakeholders were not asked to rank the research questions by EHC criteria during the first prioritization round. The votes for each research question were totaled are listed in Appendix F. The items with four or fewer votes were removed from the second round as lower priority needs.

The final prioritization round was conducted using a self-administered Web-based prioritization software REDCap^™^, developed by Vanderbilt Institute for Clinical and Translational Research. Up to two reminders were sent by email. We asked the stakeholders to rank each of the top-tier research questions using a modified version of the Effective Health Care (EHC) selection criteria called PiCMe. We asked stakeholders to rank each of the seven modified EHC selection criteria from 1 to 5 for each of the research questions, with 1 being the lowest priority and 5 being the highest priority for each of the criteria. The survey was sent electronically to participants on June 7 to June 15, 2012 (Appendix G).