# Contributors

Peter Bell, M.B.A.

Autism Speaks

Princeton, NJ

Somer L. Bishop, Ph.D.

Cincinnati Children’s Hospital

Cincinnati, OH

Edwin H. Cook, Jr., M.D.

University of Illinois at Chicago

Chicago, IL

Patricia Howlin, Ph.D.

King’s College

London, England

Lawrence Scahill, M.S.N., Ph.D.

Yale University

New Haven, CT

Tristram Smith, Ph.D.

University of Rochester

Rochester, NY

Peter Szatmari, M.D., M.Sc

McMaster University

Hamilton, Ontario, Canada