# Executive Summary

## Background

This Future Research Needs (FRN) report is based on the Agency for Healthcare Research and Quality (AHRQ) comparative effectiveness review, Interventions for Adolescents and Young Adults With Autism Spectrum Disorders.

The Key Questions (KQs) from this review were:

- KQ1: Among adolescents and young adults with Autism Spectrum Disorders (ASD), what are the effects of available interventions on the core symptoms of ASD?
- KQ2: Among adolescents and young adults with ASD, what are the effects of available interventions on common medical and mental health comorbidities (e.g., epilepsy, sleep disorders, motor impairments, obesity, depression, anxiety, acute and episodic aggression, attention deficit hyperactivity disorder, etc.)?
- KQ3: Among adolescents and young adults with ASD, what are the effects of available interventions on functional behavior, attainment of goals toward independence, educational attainment, occupational/vocational attainment, life satisfaction, access to health and other services, legal outcomes, and social outcomes?
- KQ4: Among adolescents and young adults with ASD, what is the effectiveness of interventions designed to support the transitioning process, specifically to affect attainment of goals toward independence, educational attainment, occupational/vocational attainment, life satisfaction, access to health and other services, legal outcomes, and social outcomes?
- KQ5: Among adolescents and young adults with ASD, what harms are associated with available interventions? (Harms are defined by the Effective Health Care Program as all possible adverse consequences of an intervention, including adverse events.)
- KQ6: What are the effects of interventions on family outcomes?

Findings from the comparative effectiveness review identified 32 studies, of which 10 were randomized controlled trials (RCTs). Most studies were of poor quality; only 5 were fair quality and none were good quality. Strength of evidence was uniformly insufficient for all KQs. Fourteen studies addressed the core symptoms (impairments in communication, social interaction, or behavior) of ASD (KQ1) and the effects of interventions on functional and adaptive behavior (KQ3). Nine studies addressed medical interventions (KQ2).

Harms of interventions (KQ5) were only discussed in studies of medical approaches. One study addressed interventions targeting the transition process (KQ 4), and two assessed effects of an intervention on family outcomes (KQ6).

Across all intervention types, research is needed on which outcomes to use in future studies. No studies provide adequate information on longer term outcomes, and particularly on outcomes related to achieving goals for independence and quality of life. Research is also necessary to understand how individuals’ expression of ASD symptoms and the severity of symptoms may affect treatment over the lifespan. Despite a growing population of adolescents and young adults who have diagnoses of an ASD and the need for effective intervention across the lifespan, very little research is available to guide therapy in adolescents and young adults with ASD. Overall, there is a dearth of evidence in all areas of care for adolescents and young adults with ASD, and it is urgent that more rigorous studies be developed and conducted.

## Methods

### Stakeholder Engagement

Stakeholders were identified from initial lists developed for potential Key Informants and Technical Expert Panel members for autism reviews. We sought representation from experts in treatment for adolescents and young adults, researchers focusing on this age group, advocates, and family members.

### Identifying Evidence Gaps and Developing PICOTS

We extracted a preliminary list of future research gaps as identified in our draft review and translated the identified research gaps into researchable questions. During our stakeholder teleconference call, we further refined the initial list of research questions and stakeholders identified additional gaps. We sent a snowball survey by email to solicit any additional comments and questions after the teleconference call. We reviewed stakeholder responses from the teleconference call and snowball survey, and developed a refined list of research questions. We then categorized research needs by PICOTS (participants, interventions, comparator(s), outcomes, timings, and setting) elements. We compiled the research needs/methodological issues that fell outside of our scope of our draft review related to therapies for adolescents and young adults with ASD into Appendix A of the full report. We did not ask stakeholders to prioritize these out of scope needs.

### Criteria for Prioritizing Evidence Gaps

Methods for developing future research needs are listed in Table A below. We identified stakeholders from multiple areas of expertise (clinical, psychopharmacological, behavioral, parents/advocates) to help ensure broad representation of viewpoints. Each stakeholder submitted conflict of interest documentation and curriculum vitae that was approved by the AHRQ Task Order Officer. We conducted one conference call with stakeholders and gave stakeholders the opportunity to comment on the initial list of research questions during the snowball survey after the teleconference call. We then refined the comprehensive list of research gaps related to therapies for adolescents and young adults with ASD after reviewing the teleconference responses and snowball survey.

Table A Methods for developing future research needs

Approach to Evidence Gap Identification | 1 Generate preliminary list of research gaps related to interventions for adolescents and young adults with ASD based on the gaps noted in the CER; 2 Form stakeholder workgroup with representatives from groups including patient/family/advocacy organizations, the provider community, the research community, and funding agencies; 3 Locate ongoing trials and other funded research; 4 Conduct conference call with stakeholders to refine initial list of evidence gaps; 5 Review teleconference responses and refine list of research gaps related to interventions for adolescents and young adults with ASD
Approach to Prioritization and Stakeholder Engagement for Prioritization | 6 Request that stakeholders prioritize research gaps; 7 Cull list of prioritized gaps to top tier research needs based on stakeholder voting; 8 Request that stakeholders assess top priority needs using modified EHC selection criteria
Approach to Research Question Development and Considerations for Potential Research Designs | 9 Determine potential study designs to address final list of research needs; 10 Develop research needs report; 11 Request stakeholder input on the draft research needs report; 12 Finalize research needs report

CER = comparative effectiveness review; EHC = Effective Health Care Program; ASD = autism spectrum disorders

### Development of List of Research Questions

We requested that stakeholders prioritize the expanded list of research needs via a Web-based prioritization survey that asked stakeholders to allot a number of votes to each question to indicate priority. We asked stakeholders to consider overall importance of the question for interventions for adolescents and young adults with ASD but did not proscribe specific criteria for prioritizing at this phase. We limited the number of votes available to two-thirds of the number of questions identified to ensure that stakeholders selected high priority issues. We then compiled votes across stakeholders and questions to determine the top tier research needs. We determined that the cutoff for top tier and bottom tier was five or more votes allotted to each individual question. By using these criteria, it allowed us to move forward 12 questions (roughly half) to the next prioritization round for further ranking by Effective Health Care criteria.

We sent a second Web-based survey to stakeholders and asked them to prioritize the top-tier needs using modified EHC program selection criteria (Prioritization Criteria Methods [PiCMe]).

- Potential for significant health impact
- Potential to reduce variation in clinical practices
- Potential for significant economic impact
- Potential risk from inaction
- Potential to address inequities
- Potential to allow assessment of ethical, legal, social issues pertaining to the condition
- Potential for new knowledge

Stakeholders ranked each question on each of the criteria using a 1 (low) to 5 (high) point scale. We tallied scores across each criterion to determine an overall score for each question. We tallied the scores for each question on each criterion to determine on overall score and considered questions by a range of scores into top, middle, and lower tiers.

## Results

In the draft review we identified significant gaps in the research literature addressing adolescents and young adults with ASD. We then developed the list of preliminary evidence gaps into research questions organized by KQs, based on information from the draft review input from our stakeholders. In the first prioritization survey, stakeholders were allowed to distribute a specific number of points across the potential research questions as they saw fit. The total number of points available to be allotted was 18 and they could put as many or as few as they selected on individual questions to indicate how strongly they felt about the particular questions, up to a total of 18. The highest priority questions (questions scoring at least 5 points, n = 12/27 needs) identified via the first prioritization survey were organized by broad area of focus and in no particular order. Twelve research questions received five or more votes, and were considered the top-tier priorities after the first prioritization round. The remaining lower tier questions with four or fewer votes did not advance to the final prioritization round.

We then asked stakeholders to prioritize each of the 12 high-priority research questions using the EHC criteria during the second prioritization survey. Six out of seven stakeholders completed the survey. We tallied the scores for each question on each criterion to determine on overall score and considered questions by a range of scores into top, middle, and lower tiers. The research needs are not listed in order of priority and are all considered of high importance. The details of each top priority future research questions are listed below in Table B with PICOTS and potential study considerations, and Table C lists the top tier methods questions/foundational research identified in the final round.

Table B Top-tier treatment-related research questions with detail

Research Question | Tier | Relevant PICOTS Area(s) | Study Considerations
What is the effectiveness of available interventions for treating behavioral issues (e.g., aggression, self-injury, and other challenging behaviors) during transition years in adolescents and young adults with ASD? | High | Population: Adolescents and young adults with ASD Intervention: Manualized ABA-based interventions Comparators: Drug + ABA Drug + Manualized psychotherapy Manualized psychotherapy Outcomes: Measures of health care utilization, hospitalization, and psychotropic drug use; Family functioning Timing: 16 weeks + followup | Appropriate control groups are essential and interventions should be manualized to allow replication.
What is the effectiveness of early intervention programs to improve functional behavior in adolescents and young adults with ASD? | High | Population: Children, adolescents and young adults with ASD Intervention: ABA-based interventions in early childhood Comparators: Community based services Outcomes: Improvement of functional behavior over long periods of time into adolescence and adulthood | Prospective studies are needed, despite the challenge of following children through childhood and adolescence. Randomization may be impossible so ascertainment and control for confounding variables is especially important.
What is the effectiveness of available manualized transition programs (e.g., work readiness programs, vocational programs, person-centered planning, training programs) in ASD? | High | Population: Adolescents and young adults with ASD Intervention: Manualized transition programs(e.g., work readiness programs, vocational programs, person-centered planning, training programs) Comparators: No participation in transition programs or other types of transition programs Outcomes: Hours out of the home (e.g., volunteering, working) to measure behavioral flexibility; Functional engagement; Family hours working/increase in income | Randomization is ideal, or very good characterization of participants for analysis. Investigators need ways to identify the “active ingredient” in these interventions, and should report longer term outcomes and outcomes other than simply having employment.
What is the effectiveness of community-based programs (e.g., private ABA schools, Cognitive Behavior Therapy (CBT) programs, social skills programs) to provide care for adolescents and young adults with ASD? | High | Population: Adolescents and young adults with ASD Intervention: Community based programs (e.g., private ABA schools, Cognitive Behavior Therapy (CBT) programs, social skills programs) Comparators: No participation in community-based programs or other types of community-based programs Outcomes: Measures of social engagement; participation in external activities Setting: School based, community based | Randomization is ideal, or very good characterization of participants for analysis. Investigators need ways to identify the “active ingredient” in these interventions, and should report participant-centered outcomes.

Table C Top-tier methods/foundational research

Methods/Other Related Research Questions | Tier
What measurable psychiatric and medical comorbidities predict less successful transition from supportive educational settings as well as affect quality of life metrics? | Top

## Discussion

The purpose of this project was to generate a list of high-priority future research needs for interventions for adolescents and young adult with ASD, soliciting stakeholder input through a multistep process. Throughout the conference call and snowballing survey, stakeholders emphasized several needs that included: (1) strategies for transition and support including predictors for successful transition; (2) quality of life measurements for the individual and family members (life satisfaction, measures on success); (3) interventions implemented in the community; (4) assessment of comorbidities during adolescent and transition years; (5) evaluation of programs (vocational, work-readiness, community, and transitional); and (6) harms related to intervention programs for both the individual and family members. Stakeholders focused on behavioral, evaluation of transitional programs, and quality of life measures for the individual and family members. The stakeholders reiterated the critical need for fundamental studies on adolescent and young adults with ASD in all areas. While there was substantial overlap between what the team had identified as research needs in the original CER, and those identified in this process, the stakeholders were instrumental in providing additional detail and in prioritizing which questions should be of highest priority at this time.

The final list includes research questions and priorities that center on identifying methodologies and evaluating interventions during fairly critical developmental timeframes where specific emergent issues are quite common. More specifically, this list highlights the import of issues related to accurately assessing and ameliorating the impact psychiatric comorbidity for this population, developing and understanding the impact of well-defined treatments for some of the most impairing emergent acute behavioral issues and challenges during this time, and specific programs aimed at moving adolescents and adults from supportive educational environments to meaningful work settings. There was also a specific priority set for understanding the broad swath of common interventions often supplied and supported for this population that as yet do not have sufficient evidence base to understand impact of such programs on individual or population levels. Interestingly, one top-priority research question focused not specifically on interventions for this age range per se, but focused on measuring the effect of earlier interventions on the functioning of adolescents and young adults. This last point highlights the limits of studies and reviews confined to specific age-points as ASD represents a lifespan disorder and interventions and their evaluation must clearly understand individuals over years and decades rather than months to truly understand and evaluate impact.

These research priorities highlight several gaps as well as limits in foundational and methodological knowledge base likely critical for understanding the comparative efficacy of interventions for adolescents and young adults. Primarily, these priorities highlight the fundamental lack of sufficiently rigorous evaluations of the development and course of ASD across the lifespan that would help identify specific lifespan oriented trajectories and elucidate appropriate treatment targets and context. More simply, an enhanced understanding of the course of the disorder is necessary to help guide decisions about what some of the important targets should be and in turn what the most promising interventions might be.

The current identified priorities stress that we do not yet understand the best modalities for treating emergent acute focal impairments much less the complex and dynamic neuropsychiatric and developmental vulnerabilities that emerge over this timeframe. Given the tremendous heterogeneity of the disorder and complex interactions of this heterogeneity with developmental, educational, intervention, familial, and system factors, it is clear that hoping to identify simple, single treatments for the multitude of impairments across and within individuals and environments over time is unlikely. What is more likely is that specific focal issues, relative to individual levels of impairment and developmental status and potentially responsive to interventions, could be identified and evaluated in more rigorous form. Identification of critical interventions at critical points of vulnerability that improve functioning relative to level of impairment would help promote movement toward realistic individualized intervention decisions.

The identified priorities relating to understanding transitional vocational intervention paradigms highlights this fact. At present, there is not yet a sufficient evidence base to guide what programs could be implemented for whom and toward what level of effect. In simpler terms, expanded scope of study in terms of time frame (e.g., from childhood to adolescence to adulthood) across the range of individual abilities associated with ASD is clearly necessary. In this regard, as suggested by our respondents, identifying specific methodologies for appropriately indexing change across these outcomes is also a necessity to help achieve progress toward these priorities.

Challenges presented by this process included scheduling conflicts with stakeholders and incomplete participation from one member. Two of our stakeholders with pharmacological backgrounds were unable to participate in the teleconference call due to scheduling conflicts, which may have contributed to the lack of potential research gaps in harms, or psychopharmacological research. We did, however, allow everyone time to add any additional comments/questions during the snowballing survey. Second, the small sample size of our stakeholder panel limited the generalizability of our findings. Finally, although every attempt was made to engage a balanced group of stakeholders, the group consisted mainly of clinicians with one family member and advocate. One other challenge was identifying an appropriate cutoff point for top tier ranking. We decided on a cutoff of five or more votes to move into the final prioritization round, roughly half of our initial list of research questions. The final results should all be viewed as highest priority needs, and are not ranked in any particular order.

## Conclusion

Four intervention studies were identified as highest priority. Interventions that warrant rigorous evaluation include: those intended to treat behavioral issues, including aggression and self-injury; long-term impact of early intervention provided in childhood; manualized transition programs; and community-based programs targeting adolescents. In all cases, prospective studies should be conducted, either in the form of RCTs or cohort studies that include appropriate comparison groups and rigorous assessment and analytic management of confounding variables. In order to best conduct these studies, foundational research should also be conducted to better understand the degree to which psychiatric and medical comorbidities may affect successful transition to adulthood, and to better describe the trajectory faced by maturing adolescents and young adults with autism.