# Discussion

The purpose of this project was to generate high-priority future research needs for study of interventions for adolescents and young adult with ASD soliciting stakeholder input through a multistep process. We engaged stakeholders in the first part of this future research needs project to explore potential research needs for each of the KQs from the draft review, and further developed the list of identified research gaps. During the prioritization round and the final prioritization, we asked the stakeholders to allot votes in order of importance/high-priority and then again using a modified version of EHC criteria (PiCMe). The draft evidence review discussed the small and methodologically flawed evidence base, which is inadequate to inform treatment decisions for a large and growing segment of the population. As little research exists, gaps occur in outcomes reported and interventions assessed. Gaps also occur in the characterization of populations in studies and the duration of studies.

Autism spectrum disorders are lifelong disabilities and are among the most common neurodevelopmental disorders, with an estimated prevalence of one in 88 children in the United States having ASD.1 Though the Centers for Disease Control and Prevention data do not include analysis by age group, they suggest that there are a significant number of adolescents and young adults currently affected by ASD, as well as a large cohort of children with ASD approaching the adolescent range.

We identified current and ongoing studies using the criteria from the original review. We identified randomized controlled trials (RCTs) that address a range of topics including drug therapy, behavioral interventions, dietary or supplement-based interventions and studies in complementary and alternative medicine. The majority of the RCTs were not exclusive to the age limit of the original review (ages 13 to 30), but overlapped either studies of children up to age 18 or studies of adults 18 years of age and older. There is a dearth of RCTs focused solely on adolescent and young adults (ages 13 to 30) with ASD.

Seven stakeholders accepted our invitation to participate in the future research needs project to identify and prioritize research needs. We attempted to solicit stakeholders from multiple areas of expertise (clinical, psychopharmacology, behavioral, parents/advocates) to help ensure broad representation of viewpoints. We conducted one conference call with stakeholders to refine the initial list of evidence gaps and gave stakeholders the opportunity to comment on the initial list of research questions through email during the snowball survey after the teleconference call.

Throughout the conference call and snowball survey, stakeholders emphasized several needs that included: (1) strategies for transition and support, as well as predictors for successful transition; (2) quality of life measurements for the individual and family members (life satisfaction, measures on success); (3) interventions implemented in the community; (4) assessment of comorbidities during adolescent and transition years; (5) evaluation of programs (vocational, work-readiness, community, and transitional); and (6) harms related to intervention programs for both the individual and family members. Stakeholders focused on behavioral, transitional, and quality of life measures for the individual and family members. The stakeholders reiterated the critical need for fundamental studies on adolescent and young adults with ASD in all areas.

The final list includes research questions and priorities that center on identifying methodologies and evaluating interventions during fairly critical developmental timeframes where specific emergent issues are quite common. More specifically, this list highlights the import of issues related to accurately assessing and ameliorating the impact of psychiatric comorbidity; developing and understanding the impact of well-defined treatments for some of the most impairing behavioral problems; and studying specific programs aimed at moving adolescents and adults from supportive educational environments to meaningful work settings. There was also a specific priority set for understanding the broad swath of common interventions for this population that as yet do not have a sufficient evidence base to understand their impact. Interestingly, one research question of top priority focused not specifically on interventions for this age range per se but rather on measuring the effect of earlier interventions on the functioning of adolescents and young adults. This last point highlights the limits of studies and reviews confined to specific age-points as ASD truly represents a lifespan disorder, and outcomes must be studied over years and decades to truly understand impact.

These research priorities highlight several gaps as well as limits in the foundational and methodological knowledge base critical for understanding the comparative effectiveness of interventions during adolescence and young adults. Primarily, these priorities highlight the lack of sufficiently rigorous evaluations of ASD across the lifespan. An enhanced understanding of the course of the disorder is necessary to help guide decisions about what some of the important targets should be and, in turn, what the most promising interventions might be.

The current identified priorities stress that we do not yet understand the best modalities for treating impairments, much less the complex and dynamic neuropsychiatric and developmental vulnerabilities that emerge over this timeframe. Given the tremendous heterogeneity of the disorder and complex interactions of this heterogeneity with developmental, educational, intervention, familial, and system factors, it is clear that simple, single treatments are unlikely to address the multitude of impairments across and within individuals and environments. Instead, specific focal issues might be responsive to interventions in some individuals at particular developmental timepoints, when they could be rigorously evaluated. Identification of interventions at critical points of vulnerability would promote more realistic individualized intervention decisions.

The identified priorities related to transitional vocational interventions highlights the need for more data. At present, there is not yet a sufficient evidence base to guide what programs could be implemented for whom toward what level of effect. In simpler terms, the current scope of ASD research needs to expand in terms of time frame (e.g., from childhood to adolescence to adulthood) and across the range of individual abilities associated with ASD. As suggested by our respondents, the field needs to identify specific tools for indexing transitional outcomes.

Our research methodology had some limitations that deserve discussion. First, although the survey included a broad range of topics, it did not emphasize psychopharmacological questions. Challenges presented by this process included scheduling conflicts with stakeholders, and led to incomplete participation from one member. Two of our stakeholders with pharmacological backgrounds were unable to participate in the teleconference call due to schedule conflicts, and might have missed potential research gaps in harms or psychopharmacological research. Second, the small sample size of our stakeholder panel limits the generalizability of our findings.

Finally, although every attempt was made to engage a balanced group of stakeholders, the group of consisted mainly of clinicians with one family member and advocate. Challenges presented by this process included scheduling conflicts and led to incomplete participation from one member. One other challenge was identifying an appropriate cutoff point for top-tier ranking. We decided our cutoff would be five or more points to move into the final prioritization round; roughly half of our initial list of research questions. The final results should all be viewed as highest priority needs, and are not ranked in any particular order.