# Conclusions

Four intervention studies were identified as highest priority. Interventions that warrant rigorous evaluation include those intended to treat behavioral issues, including aggression and self-injury, long-term impact of early intervention provided in childhood, manualized transition programs, and community-based programs targeting adolescents. In all cases, prospective studies should be conducted, either in the form of RCTs or cohort studies that include appropriate comparison groups and rigorous assessment and analytic management of confounding variables. In order to best conduct these studies, foundational research should also be conducted to better understand the degree to which psychiatric and medical comorbidities may affect successful transition to adulthood, and to better describe the trajectory faced by adolescents and young adults with autism as they mature.